# METHODS

## Key Questions Addressed

In order to meet the objectives of this report, we address the following Key Questions:

1. How is a nonunion fracture diagnosed?
2. What are the risk factors for developing a nonunion fracture?
3. What are the current standards of care for nonunion fractures?
  a. What supportive measures are recommended?
  b. What surgical therapies are currently recommended for treatment of nonunion?
  c. What orthobiologics and external devices for stimulation of bone healing in nonunion fractures have been approved by the FDA and which have not been approved by the FDA?
4. What are the intermediate and patient-reported outcomes of treatment for nonunions, and how are they defined?
5. What is the evidence for variations in outcomes attributable to surgeon, procedure and institution characteristics?
6. What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

## Literature Searches

Details of our search strategies used in searching 10 electronic databases, hand searches of the bibliographies of all retrieved articles, and searches of the gray literature are presented in Appendix A.

## Inclusion/Exclusion Criteria

For Key Questions 1, 2, 3a, 3b and 4, we included reviews, clinical practice guidelines, and orthopedic textbooks published between 1990 and 2005. Based on recommendations from our orthopedic consultant,(53) we relied heavily on chapters in the text, Rockwood and Green’s Fractures in Adults.(54) A limited number of illustrative clinical studies are included as supplements to information in these sources. In addition, studies included for Key Question 6 were used as sources for the list of most frequently used outcome measures addressed in Key Question 4.

For Key Question 3c, we examined the U.S. Food and Drug Administration’s pre-market approval (PMA) and 510(k) databases for approvals and marketing clearance for orthobiologics and external bone growth stimulating devices specifically indicated for the treatment of nonunion fractures. For non-FDA approved orthobiologics and external bone growth stimulating devices being used to treat nonunion fractures, we examined all of the included and excluded studies examined for Key Question 6, FDA News, Current Healthcare News, Medscape, the Web sites of AAOS, OTA and AOFAS, and Clinicaltrials.gov.

For Key Question 5, we included only publications from 1990 to 2005 that explicitly linked variations in practice with respect to surgeon, procedure, and institution characteristics to outcomes of treatment.

For Key Question 6, this report systematically reviews clinical studies of bone growth stimulating devices and orthobiologics to assess their role in enhancing the healing process of nonunion fractures. We identified clinical studies relevant to Key Question 6 through electronic and manual searches of literature published between 1990 and 2005. A draft report was submitted for external review to a variety of interested parties, including representatives from orthopedic surgery, manufacturers of bone growth stimulating devices, AHRQ and CMS. This process resulted in a supplemental search for the period 1975 to 1990 to expand the information pertinent to electrical bone growth stimulating devices. Additional articles were identified by reviewers, and in one case, a translation of a study of ultrasound therapy published in German was provided to us.(1)

Abstracts presented for the past 2 years at the American Academy of Orthopedic Surgeons (AAOS), the Orthopedic Trauma Association (OTA) and the American Orthopedic Foot and Ankle Society (AOFAS) meetings were reviewed to identify studies relevant to Key Question 6. Studies identified from the supplemental search and the meeting abstracts are discussed in the body of this report, but are not included in the full evidence tables in the Appendices.

We used the following criteria to determine which studies would be included in our analysis for Key Question 6:

1. Studies published in English. (A translated study provided to us is discussed to provide additional information on ultrasound technology.)
2. Articles published from 1990 to the present. (Studies of bone growth stimulating devices conducted prior to 1990 which otherwise meet our inclusion criteria are discussed to provide historical context for more recent publications included in the systematic review.)
3. Studies of adult humans. The developmental processes involved in bone growth prior to adulthood lead to additional complexities in the treatment of nonunions which are not relevant in the general Medicare population. We did not exclude studies which included a small number of individuals younger than 18 years of age.
4. Studies using controlled, cohort, and case series designs. Controlled studies are the preferred study design for sorting out the influence of the treatment under study from other potential influences. While we did not identify long-term studies to substantiate the belief that nonunions will not heal without further intervention, there appears to be consensus in the orthopedic community that this is the case. Therefore, carefully designed case series that reduce the potential that other aspects of treatment are responsible for healing may provide valid evidence of device or orthobiologic effectiveness. ECRI proposes a careful evaluation of uncontrolled studies in this systematic review to judge the quality and validity of their results.
5. Studies including 20 or more patients. The primary outcome of interest in the studies examined for this report is the percentage of treatment successes (healed nonunions) and failures (continued nonunions). We chose 20 patients as the minimum for inclusion given the predominance of case series. In order to be reasonably confident that reported success rates with treatment were not due to chance, we calculated 95% confidence intervals (using the Wilson Score Method(55,56)) for groups of varying sizes. The 95% confidence interval calculated for a success rate of 70% in a group of 10 patients is 40% to 90%. The confidence interval for the 30% failure rate in this group would be 11% to 60%. With 10 patients, there is considerable overlap in these estimates of success and failure, which are in the range of success and failure rates commonly reported. With 20 patients the confidence intervals narrow. For fifteen successes (75%) and five failures (25%) the 95% confidence intervals are 53% to 89% for the success rate and 11% to 47% for the failure rate. The confidence intervals will decrease further as patient numbers increase, but we considered 20 patients a reasonable minimum number for comparing these series to published success rates for other treatments of nonunion. We followed the commonly accepted practice of requiring at least 10 patients per group for controlled studies.
6. Studies published as full papers. We also reviewed recent abstracts to supplement our review, but did not assign them the same status as full papers.
7. Only the most recent publication of any study reported in multiple publications to avoid duplication of data.

Additional criteria specific to individual questions are presented in the Results section under each Key Question.

## Data Extraction

Information extracted from the included studies for Key Question 6 is presented in Evidence Tables in Appendix C. These tables describe study results, design details, information on enrolled patients, information on the treatment procedures used in each study, and study results.

We have only extracted outcome data relevant to the Key Questions in this report. If relevant data were reported in figures but not in text, we estimated them from the figures. When study authors did not report dichotomous data as percentages, we computed percentages.

## Evaluation of the Quality of the Evidence Base

For Key Question 6, we rated evidence strength and internal validity using standard criteria as proposed by the U.S. Preventive Services Task Force (USPSTF). The first step in this process involves identifying the study design and labeling it according to the hierarchy shown in Table 1.(57)

Table 1 Hierarchy of Research Design (USPSTF)

Level | Definition
I | Evidence obtained from at least one properly randomized controlled trial.
II-1 | Evidence obtained from well-designed controlled trials without randomization.
II-2 | Evidence obtained from well-designed cohort or case-control analytic studies, preferably from more than one center or research group.
II-3 | Evidence obtained from multiple time series with or without the intervention. Dramatic results in uncontrolled experiments (e.g., penicillin) also qualify.
III | Opinions of respected authorities, based on clinical experience, descriptive studies and case reports, or reports of expert committees.

In recent years USPSTF has recognized that this hierarchy by itself gives inadequate consideration of internal validity (how well a study was conducted). For example, a well-designed cohort study may be of higher quality than a poorly-conducted randomized controlled trial. Therefore, they adopted an additional system for ranking internal validity (“good”, “fair”, or “poor”). A “good” rating means that a study meets all criteria for that particular study design, a “fair” study does not meet all criteria but is judged to have no fatal flaw that invalidates its results, and a “poor” study contains a fatal flaw.(57) Table 2 presents the criteria used by the USPSTF to judge internal validity. We gave each criteria a ‘yes’ if the study met that criteria and a ‘no’ if the study did not. A “good” study had all yeses, a “fair” study had one or two no’s. We have added an additional category called “low” if the study had three or more no’s, which describes a study that is borderline acceptable (not quite “fair”, but not necessarily fatally flawed). Any fatally flawed studies were excluded. We listed both the USPSTF hierarchy level and the validity results in each of the evidence tables in Appendix D for included studies addressing Key Question 6.

Table 2 Criteria for Grading the Internal Validity of Individual Studies (USPSTF)

Criteria for Randomized controlled trials and cohort studies
1. Initial assembly of comparable groups:; - For RCTs: adequate randomization, including concealment and whether potential confounders were distributed equally among groups.; - For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts (We considered prospective case series reporting consecutive patients to be ‘yes’ and retrospective case series to be ‘no”); 2. Maintenance of comparable groups, includes attrition, crossovers, adherence, and contamination. (We considered this to be ‘no’ if attrition or dropouts were not reported); 3. Important differential loss to followup or overall high loss to followup. (We considered this to be ‘no’ if attrition was over 20%); 4. Measurements: equal, reliable, and valid, includes masking of outcome assessment. (We considered this to be ‘no’ if outcome assessment was not blinded/masked); 5. Clear definition of interventions; 6. All important outcomes considered. (Studies should report radiographic evidence of healing, pain, and weight-bearing to be considered a ‘yes’); 7. Analysis: adjustments for potential confounders for cohort studies, or intention-to-treat analysis for RCTs. (We considered this to be a ‘no’ if the study did not report statistical analysis.)

We estimated the generalizability of each study to the U.S. Medicare population using study enrollment criteria and the reported characteristics of the patients who were actually enrolled in the study. This information is presented in the Evidence Tables in Appendix D.