# EVIDENCE SYNTHESIS

Because each Key Question had a different evidence base, we describe each evidence base separately under the relevant Key Question.

## Key Question 1 How is a nonunion fracture diagnosed?

This question was addressed using reviews, clinical practice guidelines, orthopedic textbooks and selected clinical studies published between 1990 and 2005. Based on recommendations from our orthopedic consultant,(53) we also used chapters in the text, Rockwood and Green’s Fractures in Adults.(54) Selected clinical studies are included as supplements to information in these sources.

Nonunion is the failure of a fracture to unite over an expected period of time. In a recent review, Smith et al.(58) stated that “clearly, a fracture that fails to show progressive evidence of healing over a 4- to 6-month period can be considered a nonunion.” However, in a cross-sectional survey of 444 orthopedists, Bhandari et al.(2) found that there was a range in time to declaration of nonunion in the tibial shaft of 2 – 12 months (mean of 6 months, SD 2 months), as well as variations in the use and weight given to radiographic and clinical characteristics.

Some variation in expected time to fracture union reflects different healing rates for different bones.(53) Bones and regions of bones with relatively more cancellous bone and greater vascularity heal more quickly than those with predominantly cortical bone. For a given anatomic location, characteristics of the fracture also determine expected healing rates. For example, Court-Brown et al. evaluated 438 patients with closed tibial fractures and 109 patients with open tibial fractures, finding a mean healing time of 12 weeks in the simplest closed fractures (n = 38) but a mean of 56 weeks in the most severe open fractures (n = 12).(3) A systematic review of epidemiologic studies of time to healing of acute fractures with specific characteristics (e.g., open vs. closed) for specific bones (and regions of those bones) was beyond the scope of this report, but could be useful for clarifying criteria for delayed union. Once an assessment is made that healing is delayed, most authors define nonunion as the absence of signs of healing for an additional 3 months, although there is not unanimity on this definition.

The radiographic features used for diagnosis of nonunion include the size and shape of callus formation, the continuity of the cortex, the visibility of the fracture line, and the position and integrity of hardware used in the initial treatment.(2) In the survey conducted by Bhandari et al., roughly 40% of surgeons responding stated that they “always” used these features to diagnose nonunion.(2) Plain films of fracture sites are typically taken in orthogonal projections. Additional views to further assess the progress of healing may include oblique projections and stress views. Radiographic evidence of fracture healing lags behind actual healing, as mineralization of the new bone formed occurs late in the process. For example, Ring noted that fractures in the hand can heal uneventfully despite persistence of a fracture line for as long as a year following injury.(59) Other imaging studies may be used to supplement plain films. Standard tomography provides greater detail than plain films and may show persistent fracture lines more clearly.(60) Computerized tomography is a particularly useful imaging modality for more accurately assessing nonunion.(53) The shape of callus formed is described as “elephant’s foot type” (with abundant callus) or “horse-shoe” type in hypertrophic nonunions. Atrophic nonunions demonstrate minimal to no callus and resorption of the ends of the bone fragments. Oligotrophic nonunions are intermediate in character between hypertrophic and atrophic nonunions.(32,58)

MRI may be particularly helpful for determining whether infection is present with nonunion when the presence of hardware does not preclude its use. Radionuclide scans of various types may be used to determine whether there is osteonecrosis or infection, but tissue biopsy may be necessary in some instances. One case series we identified examined the use of ultrasound in addition to standard x-rays to follow fracture healing over a one-year follow-up period, and noted that ultrasound demonstrated multiple bone fragments or poor alignment, loss of a linear echogenic cortical border and absence of a bony bridge in nonunions.(61)

Clinical criteria for diagnosis of nonunion include pain on palpation of the fracture site, and for the lower extremity, pain on weight-bearing. In the survey by Bhandari et al., roughly 40% of orthopedists stated that they “always” used these criteria.(2) Motion at the fracture site may be detectable on physical examination when an unstable nonunion is present.(3) These clinical findings in the absence of radiographic evidence for healing may influence the timing of diagnosis.

Court-Brown’s discussion of the diagnosis of tibial nonunion is illustrative of the difficulty in diagnosis of nonunion.(3) He notes that confirmation of a clinical suspicion of nonunion may be “surprisingly difficult” and that “even after extensive investigations, neither the radiologist nor the surgeon may be completely sure about the diagnosis, and under these circumstances, the surgeon must rely on experience, and the decision as to whether treatment is required is based on clinical grounds.”

## Key Question 2 What are the risk factors for developing a nonunion fracture?

In the chapter, “Bone and Joint Healing” in Rockwood and Green’s Fractures in Adults, Buckwalter et al. point out that while nonunion may occur in the absence of identifiable risk factors, certain injury, patient and treatment characteristics appear to predispose to nonunion.(32) Injury variables include the severity of injury both to bone and surrounding soft tissue. Open fractures are more likely to be associated with disruption of blood supply, producing necrotic bone and soft tissue which may interfere with formation of the fracture hematoma and predispose to infection. Severely comminuted fractures, whether open or closed, are also associated with severe soft tissue damage, vascular disruption and an impaired bone healing response. Soft tissue may also become interposed between fracture fragments, interfering with reduction and alignment. In contrast, less severe injuries have an “internal splint” in the form of the intact soft tissue envelope and a fracture hematoma, which serves as a source of cells and mediators which promote healing. Intraarticular fractures may be difficult to properly align and stabilize. Segmental fractures may result in a section of bone without adequate periosteal and intramedullary blood supply. Vascular disruption may be a particularly important risk factor for nonunion in bones such as the femoral neck, scaphoid and talus, which have a limited blood supply under normal circumstances. Areas with minimal surrounding soft tissue, such as the distal tibial region, also have a more limited blood supply and are at greater risk of nonunion following extensive trauma or after surgical procedures.(32)

Of the systemic risk factors, heavy smoking was mentioned in a number of reviews and case series as an important risk factor.(62–67) Obesity, alcoholism, diabetes and peripheral vascular disease were also mentioned.(68) Certain medications, including nonsteroidal anti-inflammatory drugs,(69) corticosteroids and anticoagulants are also thought to increase risk for nonunion or infection.(58) Buckwalter et al. noted that one experimental study found impaired fracture callus strength in the setting of protein deficiency.(32) Some case series describe higher rates of nonunion with increasing age,(70) but based on the study by Street et al.(52) and the discussion in the chapter by Buckwalter et al.(32) presented in the Background section on page 20 of this report, this may not be a generalizable finding. Osteoporosis does not directly interfere with fracture healing, but the decreased bone mass leaves less surface area for contact between fracture ends and the ultimate mechanical strength of the new bone formed will be less than that of nonosteoporotic bone.(32,53)

Certain aspects of fracture treatment interfere with healing, but may or may not be clinically significant. Open reduction or other surgical exposure of a fracture site disrupts the fracture hematoma and may damage the blood supply and surrounding soft tissue. Inadequate stabilization or excessive distraction of fracture fragments by internal or external fixation devices may interfere with healing. In the ideal situation, fracture fragments are in direct contact, in proper alignment and under compressive loads. However, if the periosteum and the soft tissue envelope are well-preserved, minimal separation of the fragments may not significantly deter healing. Buckwalter et al. referenced experimental studies indicating that early weight-bearing and micromotion at long bone fracture sites promotes fracture healing and that decreased loading across the fracture retards healing. Unfortunately, the optimal timing, pattern and intensity of loading is not known for individual fracture types, and could vary based on individual patient factors if it were known. Certainly, continuous and excessive motion at a fracture site is likely to cause nonunion, but the effect of instability is not consistent across various bones. For instance, closed fractures of ribs, the clavicle, humeral shaft, metacarpals and metatarsals may heal despite persistent mobility on clinical examination. In contrast, fractures of the femoral neck and scaphoid are particularly sensitive to excessive motion, and require immobilization to heal.(32)

While internal fixation devices such as compression plates provide rigid stabilization (commonly referred to as “absolute stability”), they may cause regional bone loss due to transfer of load from the fractured bone to the implant. If an implant is utilized but stability is not achieved, motion at the fracture site may cause additional stress on the bone leading to resorption, as well as stress on the implant, causing device breakage. Inadequate stabilization or immobilization of fractures was cited by several authors as a significant risk factor for nonunion, but was not necessarily attributable to surgical technique, given the nature of the fractures and the need for patients to adhere to difficult treatment plans and intensive followup. When successful, however, rigid stabilization by internal fixation is particularly helpful for treatment of fractures of the radial and ulnar shafts and intraarticular fractures.(32)

As orthopedic techniques and equipment have evolved, certain hardware and techniques have been abandoned because of excessive rates of nonunion associated with their use. For example, transverse osteotomy of the olecranon (used to expose and repair the distal humerus) was associated with a 30% nonunion rate.(71) Power reaming of the tibia and use of skeletal traction were thought to be risk factors for tibial nonunion by O’Dwyer et al.(72) Among 45 patients with tibial fractures randomized to intramedullary nailing with or without reaming, higher rates of tibial nonunions were found without reaming (3 patients) than with reaming (no patients).(73) Early intramedullary nails that did not provide adequate stability were prone to rotational and axial motion, as well as nail migration, making nonunion more likely.(74) Certain plating systems have caused vascular damage.(75)

Variations in surgical practice addressed in the articles we retrieved included the issue of time to initial surgical repair of an acute fracture. In a retrospective review of open fractures treated at the University of Alberta Hospital in Edmonton, Canada, Harley et al. found no increase in nonunion rates for 100 fractures treated more than 8 hours following injury with the majority treated within 13 hours compared to 115 treated within 8 hours. In a multivariate logistic regression model, the strongest determinants of nonunion were infection and grade of injury.(76) Roolker stated that diagnosis and appropriate immobilization of scaphoid fractures within a week of injury reduced the risk of nonunion, noting that plain films are often insufficient for diagnosis. Use of a hanging cast was an important risk factor for proximal humeral nonunion in the study by Pugh et al.(74)

## Key Question 3 What are the current standards of care for nonunion fractures?

Treatment of nonunion fractures must be individualized as no single method of treatment is applicable in all situations.(30,38) Therefore, a variety of treatment approaches have been developed to treat nonunion fractures. These include surgical placement of internal and external fixation, bone grafting, bone growth stimulators (electrical stimulation, ultrasound stimulation, high-energy extracorporeal shock waves), and orthobiologics (products created to enhance fracture healing). “Osteoinduction” is the process of recruiting mesenchymal type cells (osteogenic stem cells) which differentiate into cartilage and bone-forming cells. Recruitment of these cells is believed to occur with mechanical, electrical and chemical forces.(58) Mechanical force may be applied nonsurgically, as with functional bracing and weight-bearing, or surgically, as with compression plates or intramedullary rods to stabilize the fracture and permit weight-bearing.

To address this question, we have used recent reviews and texts, particularly Rockwood and Green’s Fractures in Adults(54), as well as input from our orthopedic consultant.(53,77) Figure 1 (page 19) illustrates a framework for choosing among the options. The discussion of the overarching principles presented in the Background section will not be repeated here, but the same framework will be used for presentation of specific treatments.

### a What supportive measures are recommended?

Supportive measures in the care of patients with fracture nonunion were mentioned infrequently in the reviews and series examined. Pugh noted that “nutritional status and smoking habits should be improved before initiating surgical treatment.”(74) As described in the section on risk factors for nonunion, a number of authors have described a higher incidence of nonunion in patients who smoke and they recommend strongly encouraging patients to avoid smoking during treatment of nonunion. Control of infection at the fracture site was also frequently cited as important. Otherwise, articles focused on the presence of comorbid conditions as factors in the choice of procedure to be performed or avoided, but good clinical practice would include stabilizing such conditions as much as possible prior to elective surgical procedures.

### b What surgical therapies are currently recommended for treatment of nonunion?

As noted previously, once nonunion is diagnosed, evaluation for infection is important early in the decision-making process (step 1 of Figure 1). If the nonunion is infected, the infection must be brought under control prior to further surgical management. If this is not possible, amputation may be the surgical therapy of choice.(53,77)

In nonunions not thought to be infected, the next decision point pertains to the distinction between “atrophic” and “hypertrophic” nonunion. Hypertrophic nonunions are viewed as a mechanical or stability problem (steps 3 - 8 of Figure 1), whereas atrophic nonunions require attention to the impairment of bone formation (steps 9 - 13 of Figure 1).(53) The means of achieving stability in the former and of stimulating bone formation in the latter depends on the location and other conditions of the fracture, in addition to the characteristics and preferences of the patient and the surgeon. The surgical management of nonunions will be discussed in the context of the anatomic regions involved, with emphasis on issues pertinent to the older population.

Bone grafting, in addition to stabilization, is an extremely important component of the treatment of nonunions in which normal growth factors and cellular mechanisms for osteoinduction are either absent or dysfunctional. Autogenous bone and bone marrow grafts contain both of these, but depend on adequate vascular supply at the nonunion site for healing to occur. In some instances, bone grafts are harvested with an intact vascular supply to overcome large bony defects. The iliac crest is the most commonly used donor site, although “local bone,” i.e., from a site close to the nonunion, is also used. Examples include use of bone from the distal tibia for repair of nonunion in the foot.(77)

ECRI has previously summarized complications and morbidities associated with harvesting bone for autografting.(78) This report cited an earlier review of harvest-site complications from the iliac crest published in 2000.(79) The latter review was based on eight studies retrieved from an online search of the National Library of Medicine database for the period 1966 - 1997 using the keywords “bone graft” and “complications.” ECRI pooled the complications across the studies included in that review and found that major complications (those requiring a major change in treatment or return to the operating room and prolonged hospital length of stay) such as deep infections, nerve injuries, and deep hematomas were reported for 1% to 2% of patients. Other major complications such as vascular damage, hernias, and fractures occurred in fewer than 1% of patients. Minor complications (those responding to non-operative intervention) were reported in 1% to 6% of patients and unsightly or hypertrophic scars in about 5% of patients. Chronic pain was reported in 20.5%.(78)

One of the studies included in the review above was a retrospective review of 239 patients (mean age 33 years) who had undergone autogenous bone grafting for a variety of indications at the University of California, Davis, Medical Center from 1982 – 1983. In this study, Younger and Chapman reported a number of complications associated with harvesting of bone. They defined major complications as those requiring increased length of stay, additional surgery or significant disability. Minor complications were defined as those responding to minor treatment or resolving without treatment. Harvest sites included the posterior iliac crest in 48%, the anterior iliac crest in 31.5% and other sites in the remainder. There were 10 patients with early major complications, including wound infections, hematomas requiring treatment and 1 broken drain requiring removal. There were 11 patients with late major complications – 6 with severe chronic pain, 3 with sensory loss, 1 with osteomyelitis and 1 with wound breakdown. In this series, 84 patients with significant comorbid conditions had a major complication rate of 14.3% in contrast to the rate of 5.8% in 155 previously healthy patients (p = 0.02).(80)

In a more recent series, Ahlmann et al. reviewed the medical records of 88 patients undergoing bone graft harvesting for limb salvage in treatment of chronic osteomyelitis between 1991 and 1998.(81) Mean age in this series was 46 years; all patients received intravenous antibiotics for five days while awaiting culture results from the site affected by the osteomyelitis. The overall major complication rate (using Younger and Chapman’s definitions) was 6% (5/66 with an anterior iliac crest harvest site and 1/42 with a posterior iliac crest harvest site).The minor complication rate was 15% (10/66 in the patients with an anterior iliac crest harvest site and 0/42 in those with a posterior harvest site). Blood loss (intraoperative and drain output) was less in the posterior site patients than in the anterior site patients (169 vs. 232 ml, p = 0.02). Fifty-eight (66%) patients completed a survey at least 2 years following the procedure. Those who had an anterior harvest site described more post-operative pain for a longer period of time (3 with pain resolving within 6 months and 1 with pain persistent after 6 months) than those with the posterior harvest site (none with pain as a complication – presumably after the early post-operative period). The authors attribute the lower incidence of complications in their series to use of antibiotics, good exposure of the donor graft site, excellent intraoperative hemostasis and use of a drain for 3 days post-operatively. They conclude by recommending posterior harvesting of iliac crest for grafting whenever possible.(81)

An unpublished study conducted by Covance Health Economics and Outcomes Services Inc. was provided to us by EBI, one of the manufacturers of non-invasive electrical bone growth stimulating devices, and is provided in Appendix E. Using the Medicare Standard Analytic Files (SAF) of claims filed for inpatient and outpatient services for a 5% random sample of Medicare beneficiaries, Covance examined claims for patients with a primary or secondary diagnosis of nonunion and a procedure code for bone grafting during the period 1995 – 1997. They also sought data on additional hospitalizations which included orthopedic procedures following the bone grafting procedure. From these claims data, they used secondary diagnoses for the initial bone grafting hospitalization to calculate complication rates of the procedure. The rates reported in their sample included 20.6% with “acute posthemorrhagic anemia,” 3.1% with urinary tract infection, 2.6% “other specified complications, not elsewhere classified,” 2.2% pulmonary collapse, 1.7% hyposmolality and 1.4% “surgical complications, urinary tract.” Other complications listed in their report are more suggestive of pre-existing comorbid conditions or indications for the procedure. We reviewed the list and incidence of complications with our consulting orthopedist, who suggested that while blood loss is an expected complication of bone grafting procedures, the bleeding is not always of clinical significance. He also noted that the diagnosis of “acute posthemorrhagic anemia” affects the diagnosis-related group (DRG) coding for surgical hospitalizations.(28) While claims data may help to identify potential complications of surgical procedures, additional studies with more complete data on patient and treatment characteristics necessary to adjust for possible confounders would be helpful for evaluating the experience of older patients.

In a recent study, 23 nonconsecutive patients with nonunion of the lower extremity were asked to complete the Short-Form Health Survey (SF-36) questionnaire prior to surgical treatment of nonunion.(82) Within the group, 5 had an infected nonunion, and all had undergone previous surgery; one had received electrical stimulation in addition to surgery. Retreatment surgery (bone grafting in 19, additional allograft in 2, reaming and exchange nailing in 6, plating and other fixation procedures) was performed at a mean of 482 days after the original treatment, and the questionnaire was administered a second time at a mean of 449 days later. By that point, 21 of the 23 nonunions had healed. There were significant improvements in the physical functioning score (baseline 23 (SEM 5.6) to 43 (SEM 6.3), p = 0.002)) and physical role score (baseline 3 (SEM 1.6) to 36 (SEM 8.0), p = 0.001)). Unfortunately, bodily pain scores did not improve (baseline 23 (SEM 4.2) to 28 (SEM 3.7), p = 0.308)). Even the post-treatment values for all of the scales remained significantly less than population norms (p <0.01 for each of the scales). The authors note that recovery may take longer than the followup in this study.

The following descriptions of surgical treatments by anatomic site are intended to highlight some of the methods of internal fixation described in reviews of the surgical management of nonunion, and is by no means a comprehensive or systematic review of the indications and complications of the associated procedures. In addition, we briefly describe use of the circular external fixator system for tibial nonunion. For each anatomic site, hardware including nails, plates, and screws are designed for use at the specific location. Long bones are treated differently depending on the location of the fracture within the bone – e.g., a fracture near a joint is often treated differently from a fracture in the midshaft of the bone. Hardware is designed to provide stability, but may stimulate bone growth in other ways as well. Bone growth is enhanced when a patient is able to bear weight after stabilization of a nonunion, as the cyclical axial load created by ambulation or active use of the extremity is an important stimulus. Reaming of long bones in conjunction with use of reamed intramedullary nails is generally believed to promote bone and vascular growth despite a temporary disruption of the endosteal blood supply. If a nonunion is well-aligned or if it can be manipulated into good alignment, nailing is performed percutaneously to reduce soft tissue trauma and propensity for infection. The force of compression across fracture fragments created by compression plates is also a stimulus to bone growth. Hardware materials, design, and surgical techniques for placement continue to evolve as better rates of nonunion are sought. Chandler presents a thorough discussion of the major types of hardware, including screws, cerclage wires, plates and nails in his chapter, “Principles of Internal Fixation” in Rockwood and Green’s Fractures in Adults in addition to appropriate usage based on fracture location and geometry.(83)

#### Sternum

Sternal nonunion may occur following cardiothoracic surgery or trauma. When the nonunion is not infected, plating with or without bone grafting may be used. Wu et al. reported successful treatment of 6 sternal nonunions treated with the Sternalock system (Sternalock, W. Lorenz Surgical, Inc.). This system uses titanium plates specifically designed for the sternum which have a locking mechanism between the plate and the screw.(84)

#### Clavicle

Nonunion of the clavicle is discussed by Lazarus in Rockwood and Green’s Fractures in Adults and specific surgical techniques are described in the text.(85) Elderly patients are most likely to fracture the outer fifth of the clavicle, and such fractures are prone to nonunion if they are displaced.(86) Some distal clavicular fracture nonunions do not impair function; in other instances, resection of the short fragment may be sufficient.(87) Plate and screw systems, with or without iliac crest grafts, have been used when surgical repair of clavicular nonunions are necessary.(88,89)

#### Humerus

Humeral fractures, while not as common as fractures of the distal radius or hip, can cause significant disability in the elderly, particularly when nonunion occurs. The humerus may be the most common site of fracture nonunion in the over 65-year old population.(74,77) Patients with unhealed humeral fractures may experience a great deal of difficulty performing basic activities of daily living. As noted previously, the review by Pugh et al. of humeral nonunions stated that the use of the hanging cast, formerly a commonly used method for management of humeral fractures in older patients, may predispose to nonunion.(74)

Proximal humeral nonunion is associated with shoulder joint contracture, rotator cuff dysfunction, and severe bone loss. Open reduction with internal fixation (ORIF) and bone grafting is typically performed in younger patients, but a shoulder hemiarthroplasty may be recommended for older patients because osteoporosis may compromise the stability of the fixation. With the emergence of “locking plates” this difficult fracture has been addressed in a much improved fashion.(90) While this procedure relieves pain, it does not typically improve function significantly.

Gregory, in his description of treatment of diaphyseal humeral fracture in Rockwood and Green’s Fractures in Adults, states that compression plating for stability, in combination with bone grafting when the nonunion is atrophic, is the current treatment of choice for nonunion of the humeral shaft.(91) The review by Pugh, et al. states that distal humeral nonunion is associated with elbow joint contracture, ulnar neuropathy and synovial pseudoarthrosis.(74) Surgical repair is complex, but if not done, severe pain and disability often result. Elbow arthrodesis may be performed to reduce pain with distal humeral nonunion, but is considered a “salvage” procedure as it results in significant disability.(74)

For each of these locations in the humerus, specific hardware and techniques have been developed for management of nonunion, following the general principles outlined above. The specific descriptions of these are beyond the scope of this report. The technical skill required for these procedures may be altered by the design of the hardware. For example, the “wave plate” used with bone grafting for diaphyseal nonunion in the study by Ring et al.(92) is said to be less technically demanding than other methods of fixation. Further, the wave plate, which is contoured to avoid contact with the cortex immediately beneath it, has the advantage of decreased resorption of bone beneath the plate compared to standard plates.(83)

Circular external fixators, described below for treatment of tibial nonunion, have also been used successfully in management of humeral nonunion.(93)

#### Forearm

Fractures of the distal radius are quite common in the elderly and are discussed by Strauss et al. in the text, Brocklehurst’s Textbook of Geriatric Medicine and Gerontology.(94) Standard treatment of an acute distal radius fracture in an older individual has traditionally been closed reduction and casting. Unfortunately, the degree of impaction that occurs with these fractures leads to bone compression, resulting in malunion and nonunion in many patients treated only by casting. More aggressive treatment of the initial fracture is now recommended.(94) The advent of “locking” distal radius plates has provided a popular and generally successful treatment alternative for nonunion of the radius.(90) In their review of distal radius fractures, Prommersberger et al. state that wrist arthrodesis may be necessary as a last resort for management of instability and pain.(68) Dynamic compression plating and screws designed for the small fragments of bone involved, coupled with autogenous bone grafting, are described in the review by Ring for management of nonunion of the radius and ulna.(95)

#### Scaphoid

Nonunion of scaphoid fractures is an important problem in younger patients, but appears to be less common in older patients.(77) A systematic review of 147 publications examining vascularized and nonvascularized bone grafting with and without internal fixation (IF) for scaphoid nonunions found that vascularized bone grafting with or without IF yielded the highest rates of union (91%), followed by vascularized bone graft with IF (84%) and nonvascularized bone graft without IF (80%).(96)

#### Hand

Ring has recently published a review of malunion and nonunion of the metacarpals and phalanges.(59) He points out that the hand cannot be immobilized for prolonged periods without permanent stiffness, and advises against immobilization for more than six weeks. In some cases, amputation may result in a superior functional outcome, particularly if there is permanent sensory loss, chronic infection, severe stiffness or insufficient skin coverage. Arthrodesis is used in conjunction with internal fixation across a stiff joint when a nonunion is periatricular. If a digit is likely to be functional once the bone heals, internal fixation using varying types of plates and screws is used to provide alignment and stability, although tenolysis and arthrolysis are usually required at the same time. Nonunions in the hand are usually atrophic, and many have bone defects, both of which necessitate bone grafting. Nonstructural, or cancellous, bone is typically sufficient for stimulation of osteogenesis, but a corticocancellous graft can be used to add some structural support and share the mechanical load with the implanted hardware. Ring cautions that even with advances in technique, however, function of digits following repair of nonunion is likely to be limited.(59)

#### Pelvis

One series of 70 late post-traumatic pelvic nonunions described patients with this condition as typically having severe pain and difficulty maintaining sitting balance. The author describes surgical treatment with debridement of the nonunion site, reapproximation of the bone fragments, bone grafting and internal fixation.(97) After surgery, 96% of the patients achieved a primary union.

#### Femur

Strauss et al., in the chapter on “Orthopedic Geriatrics” in Brocklehurst’s Textbook of Geriatric Medicine and Gerontology, state that fractures of the femoral neck may result in nonunion in 5% of patients if the fracture is not displaced, but that the rate may be as high as 35% when there is displacement. Nondisplaced fractures may be treated with internal fixation, whereas hemiarthroplasty or total hip arthroplasty is recommended for displaced fractures.(60,88,94) Intertrochanteric fractures involve cancellous bone, and consequently, they tend to heal well. Ununited femoral shaft fractures often require removal of hardware used in initial fracture management and subsequent fixation with either nailing or plates and screws.(98)

#### Tibia

Tibial fractures are the most common open fractures in the elderly.(94) As in younger patients, such fractures are at risk for infection as well as compromise of vascular supply and skin coverage. Severe soft tissue disruption may result in interposition of tissue at the fracture site that prevents bone healing. Infection may also result in sequestra which interfere similarly. Atrophic skin predisposes to wound breakdown and infection. One author commented that amputation may be preferable to the “18 months of intensive orthopedic care” and uncertain functional outcome with surgical repair of tibial nonunion.(99) Reamed intramedullary nailing was used in the majority of recent series of tibial shaft nonunions. With tibial deformity, however, compression plating was used to correct this when possible. Wiss noted, however, that the compression plate may not provide stability in patients with severe osteopenia.(30) Bone grafts and percutaneously injected marrow aspirates were used in some series.(30,88,100) To enhance the effect of axial load on bone formation, hypertrophic tibial fractures are sometimes treated by excision of a section of the fibula, causing the full force of weight-bearing to be transmitted through the tibia.(30)

ECRI previously reviewed surgical treatment for nonunion of the tibia.(78) Surgical approaches to treatment of tibial nonunions vary, but typically involve the use of a fixation device with or without a bone graft or bone-graft substitute. Hypertrophic nonunions may be treated using fixation alone. Bone grafts may not be necessary in all hypertrophic nonunions, but atrophic nonunions are likely to require osteogenic stimulation such as that provided by a bone graft.(30)

The following list briefly summarizes the commonly used surgical options for tibial nonunion:(30)

- Fibular Osteotomy. In some cases, an intact fibula may prevent close apposition of the tibial fragments and prevent compressive forces that enhance healing. Removing a small segment of the fibula can correct these problems and when combined with surgical stabilization of the tibia may also be necessary to aid in deformity correction. This procedure should not be performed to treat unstable atrophic nonunions.
- Plates. A titanium plate that spans the fracture site can be fixed with screws to either the lateral or medial aspect of the tibia. The plate helps to correct deformities, increases nonunion stability, and decreases rotational shear at the nonunion. Plating removes the need for a cast or brace. Atrophic nonunions of the tibia are typically treated with bone grafting in addition to the plate.
- Intramedullary Nailing. In this procedure, a metal rod (intramedullary nail) is placed inside the shaft of the bone. A hole is drilled at either the proximal or distal end of the bone, and the rod is passed through the length of the bone, providing mechanical strength. The medullary cavity, which occupies most of the shaft of the bone, is usually reamed before rod insertion. This procedure is used only in closed fractures and in open fractures with little deformity. Intramedullary nailing may be impossible in patients with substantial deformity.(78)

External fixation may be used alone or in conjunction with internal fixation for hypertrophic nonunion in the tibia.(101,102) An external fixator stabilizes the nonunion sufficiently to permit partial to full weight-bearing, but the need for prolonged use and frequent pin-tract infections make the device less attractive. The circular fixator, known by the name of its inventor, Ilizarov, may be used in the setting of significant bone loss, deformity or infection. A “corticotomy,” or osteotomy with preserved endosteal and periosteal blood supply, followed by bone transport, is used to provide healthy bone at the site of the defect. An external fixation apparatus attached to the limb by wires under tension creates a controlled degree of distraction of the bone ends for limited periods several times a day. Stem cells fill the distraction gap and differentiate into osteoblasts. Blood flow to the area increases by up to 40%. The device also permits full weight-bearing regardless of the size of the bony defect, adding further stimulus to bone formation.(58) The drawbacks to this approach include pin-tract infections, the need for the patient to wear the device for a prolonged period of time, the extensive inventory of equipment necessary for customizing the apparatus to the individual patient, and the difficulty of mastering the techniques of application and maintenance by the surgeon.(30)

#### Ankle and foot

When small bone fragments remain ununited in the foot following a fracture, they are sometimes simply excised to relieve pain. Otherwise, internal fixation and bone grafting techniques are used as in other locations. The distal tibia or the calcaneus may be used as harvest sites. Cortiocancellous bone is used to bridge larger defects, with special surgical techniques adapted for the location. In one procedure, the medullary canal is drilled and a “plug” of corticocancellous bone inserted. In another technique, a dorsal groove is created in the cortex of the ununited bone fragments and a bridging graft is compressed and placed across the fracture line into both segments.(103) The “Jones fracture” is a transverse or short oblique fracture at the junction of the metaphysis and diaphysis of the fifth metatarsal, entering the fourth-fifth intermetatarsal joint. The rate of nonunion for Jones fractures is 7 – 28%. Intramedullary screw fixation with bone grafting using corticocancellous bone from the tibia is typically used for management of Jones fracture nonunion.(104)

### c What orthobiologics and external devices for stimulation of bone healing in nonunion fractures have been approved by the FDA and which have not been approved by the FDA?

To address this question, we examined the U.S. Food and Drug Administration’s (FDA) pre-market approval (PMA) and 510(k) databases for approvals and marketing clearance for orthobiologics and external bone growth stimulating devices specifically indicated for the treatment of nonunion fractures. For non-FDA approved orthobiologics and external bone growth stimulating devices being used to treat nonunion fractures, we examined all of the included and excluded studies examined for Key Question 6, FDA News, Current Healthcare News, Medscape, the American Academy of Orthopaedic Surgeons Web site, the American Orthopedic Foot and Ankle Society Web site, and Clinicaltrials.gov. The list of orthobiologics and bone growth stimulating devices with potential use in the treatment of nonunion fractures are presented in Appendix B. We acknowledge that this list does not include all orthobiologics products being used for treatment of nonunion, as some of products have either not been studied specifically in the setting of nonunion but are used at the discretion of the treating surgeon.

The FDA considers most orthobiologicals to be Class II medical devices and we have listed these in Table B-1. A 510(k) is a pre-marketing submission made to FDA to demonstrate that the Class II device to be marketed is as safe and effective, that is, substantially equivalent (SE), to a legally marketed device that is not subject to premarket approval (PMA). Applicants must compare their 510(k) device to one or more similar devices currently on the U.S. market and make and support their substantial equivalency claims. The legally marketed device(s) to which equivalence is drawn is known as the “predicate” device(s). Unlike PMA, which requires demonstration of reasonable safety and effectiveness, 510(k) requires demonstration of substantial equivalence. Substantial equivalence means that the new device is as safe and effective as the predicate device(s).

FDA section 888.3045 – Resorbable calcium salt bone void filler device (Common name: bone void filler) lists these products as Class II devices. The FDA identifies the 888.3045 category as follows: “A resorbable calcium salt bone void filler device is a resorbable implant intended to fill bony voids or gaps of the extremities, spine, and pelvis that are caused by trauma or surgery and are not intrinsic to the stability of the bone structure.” In addition, “Bone void filler devices composed of alternate materials may be demonstrated to be substantially equivalent under section 510(k) of the Act to the resorbable calcium salt bone void filler device identified in this guidance document.”(105) The bone void filler category of the FDA contains 40 products with demineralized bone matrix (DBM). DBM is processed from human bone tissue using a demineralizing agent such as hydrochloric acid. The mineral content of the bone is typically reduced to less than 5% of the native levels and the remaining substance is DBM containing a variety of bone growth stimulators (osteoinductive agents such as bone morphogenetic proteins).(106,107) DBM is used in a number of bone graft substitutes. Therefore, these products may see future use in treating nonunion fractures (an FDA off label use) and some of these products are included in Table B-1. In addressing Key Question 6 of this report, we looked for clinical evidence that such off-label use of DBM products (as a substitute for autogenous bone graft material) in treating nonunion fractures improved outcomes. However, we identified only one study using a DBM product as a bone graft substitute. This study is examined in detail under Key Question 6.

The FDA has granted a “Humanitarian Device Exemption”(HDE) for use of OP-1 (BMP7) in settings where an autograft has been ineffective or not feasible and alternative treatments have failed. The single included study of this agent is discussed under Key Question 6 and summarized in Table D-6.

Table B-2 lists the external bone growth stimulating devices used to treat nonunion fractures. The medical devices listed in this table are considered to be Class III by the FDA.(108) FDA has three regulatory classes for medical devices based on the degree of control necessary to assure that the devices are safe and effective. Class III devices—those that support or sustain human life, are of substantial importance in preventing impairment of human health, or present a potential, unreasonable risk of illness or injury—are the most regulated devices. Premarket approval by the FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices. Data from clinical studies are usually required for a Class III medical device to receive a PMA.

Currently, a number of electrical stimulation devices and ultrasound devices have been approved by the FDA for treating nonunion fractures (see Table B-2). Shock wave treatment has not been approved by the FDA for use in the United States. Several studies performed in Europe have examined the efficacy of this treatment for nonunion fractures. These studies are examined in detail under Key Question 6.

## Key Question 4 What are the intermediate and patient-reported outcomes of treatment for nonunions, and how are they defined?

Bhandari et al. addressed the question of how fracture healing is assessed by surveying 577 orthopaedic surgeons.(2) Responses were received from 444 surgeons for a response rate of 77%. Three radiographic variables were most often used by the respondents: callus size, cortical continuity, and progressive loss of fracture line. The ability of the patient to bear weight on the affected limb and pain at the fracture site on palpation were the two nonradiographic methods most often used. The authors noted, however, that a lack of consensus existed among the surgeons as to which method they most often use and which methods they would not use. Cortical continuity is believed to be most directly related to return of original bone strength while callus size is the least related. Therefore, according to Bhandari et al.’s survey of orthopedic surgeons, cortical continuity would seem to be the preferred indicator of nonunion healing. However, this outcome may not be directly related to a patient’s ability to bear weight on or have full function of an appendage without pain. The survey results also indicate that surgeons often combine the radiographic evidence with evidence from clinical examination related to weight-bearing, pain on weight-bearing, pain on palpation, and movement of the nonunion. Sharrard points out that the radiographic evidence of cortical bone bridging in his study of tibial nonunions treated with PEMF stimulation or a dummy device did not match the clinical evidence of healing.(12) After 12 weeks of treatment, radiographic evidence of bridging was seen in less than half of all patients while lack of movement in the nonunion was seen in more than half of all patients. While movement of the nonunion always indicates lack of healing, lack of movement does not always indicate healing. Sharrard states that “absence of movement on clinical examination combined with radiological evidence of union seems, therefore, to be a reliable indicator of bone union.” For this report, we considered studies that used a combination of radiographic and clinical evidence of healing as superior to studies that used only radiographic evidence or only clinical evidence.

From the included studies of Key Question 6, we compiled a list of the methods used in the included studies for measuring treatment outcomes for nonunion fractures (see Appendix C). Radiographic evidence of bone bridging was used in all of the studies but various methods were used to define successful bridging, and not all studies specifically defined how this outcome was measured. Fewer studies used clinical assessments such as pain and pain on weight-bearing as outcomes related to nonunion healing.

## Key Question 5 What is the evidence for variations in outcomes attributable to surgeon, procedure and institution characteristics?

We identified no publications that directly addressed this question.

## Key Question 6 What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

### Proposed mechanisms of action

Fracture healing relies on a coordinated series of phases in which damaged nonfunctional tissue is replaced by functional tissue that restores the original structure and function. Each phase in the healing sequence relies on specific growth factors to ensure complete healing and bone restoration. Application of these growth factors directly into the fracture has been proposed as a means of enhancing bone repair.(109) The key growth factors are members of the transforming growth factor-beta (TGF-β) family. The TGF-β proteins have a broad range of cellular activities related to wound healing and to cell proliferation and differentiation in all organs of the body, especially in skeletal bone. The extracellular matrix of the bone is the largest source of TGF-β proteins in the body. In bone tissue, these proteins stimulate the production of chondrocytes, osteoblasts, and osteoclasts from precursor cells (osteogenic cells).

Another element in the repair process is the type of stress applied to the bone during healing. Chao and colleagues have proposed that biophysical stimulation plays a key role in repairing, maintaining, and remodeling of bone to meet its functional demands.(4,29) Mechanical intervention might be the only means to assure bone remodeling after callus formation and maturation in order to restore the bone to its original structure and strength. However, the direct link between biophysical stimulation and the cellular responses controlled by the various growth factors have not yet been determined. The connection may be found in the phenomenon called Wolf’s Law that relates bone stress with bone remodeling.(110) Bones under stress have increased remodeling and produce more bone matrix while bones that are not stressed undergo increased reabsorption and lose bone matrix. Osteocytes have been hypothesized as the cellular bone component that senses the changes in stress and signals osteoblasts to speed up or slow down the remodeling process. The same may be true for osteocytes in the area of a fracture. The exact mechanism by which osteocytes sense mechanical stresses and signal other bone cells is not known.

Chao and colleagues have also proposed that the biophysical stimulation needed to enhance fracture healing can be supplied through external energy such as ultrasound, pulsed electromagnetic field stimulation, low power direct current, and extracorporeal shock wave stimulation.(4) Whether these modalities produce different cellular responses or follow a similar osteogenic pathway is still controversial. The proposed mechanisms of action for each of the various external bone growth stimulators and orthobiologics are based on extensive animal and cell culture experiments.(4,109)

#### Ultrasound stimulation

Ultrasound is a form of mechanical energy that can be transmitted through tissue as acoustical pressure (sound) waves. Low intensity ultrasound used to treat nonunions does not involve heat generation or destruction of bone tissue. As the low intensity pressure wave generated by the ultrasound device passes over the surface of fracture, the tissues in the callus may be mechanically stimulated and generate a biochemical response. Ultrasound therapy may increase the expression of genes involved in bone healing, increase the secretion of growth factors, increase ossification of bone matrix, and enhance blood flow into the fracture site, all of which could contribute to the healing of nonunion fractures. Ultrasound therapy is applied for 20 minutes each day.(9,10,33,111)

#### Electrical and magnetic stimulation

Mechanical stress within bone generates electrical potentials (the potential energy measured in volts between two areas with different charges). This is known as the piezoelectric effect and may be due to shifts in the interstitial fluid and its ions as bones undergo normal compression and tension. Areas of compression become electronegative and areas of tension become electropositive. The electronegative areas produce new bone while the electropositive areas increase bone resorption. Electrical fields applied to the fracture site are thought to aid bone healing by enhancing the normal electrical potentials and upregulating the cellular processes involved in bone formation. Callus vascularization, cell proliferation, matrix protein synthesis, and secretion of growth factors may be enhanced by electrical stimulation. Electrical bone growth stimulators are of three types: direct current, capacitive coupling, and pulsed electromagnetic fields (PEMF). The proper use of externally applied electrical bone growth stimulators, capacitative coupling or PEMF usually requires patient compliance and long-term immobilization of the limb using internal fixation, external fixation, casting or bracing. Patient adherence to the treatment plan is of particular importance with PEMF given the duration of daily treatment sessions. Studies of these devices should measure patient adherence or ensure patient adherence through mechanisms built into the device.(33)

Treatment with electrical and magnetic stimulation devices may be compromised by the presence of fixation devices made from magnetic material.(112) Most of the internal and external fixation devices in current use are made from titanium alloys or cobalt-chromium alloys that are non-magnetic and are compatible with electrical and magnetic stimulation devices.(30,34,59,113–115)

Direct current – Direct current devices are considered invasive because they require that the cathode electrode (negatively charged) be implanted directly in the nonunion defect and the anode electrode (positively charged) be placed under the skin. The generator provides a constant current power source. The optimum current is between 5 and 20 microamperes. A nonweight-bearing cast must be used to prevent motion that might break or dislodge the cathode electrode. This system requires the least patient compliance because the device is always active. When the treatment period has ended, the electrodes may be surgically removed. The cathode, however, may be left in place within the bone. Compared to the other electrical stimulation systems, direct current devices produce a high local voltage gradient while the other devices produce small voltage gradients.(16,113,114)

Capacitive coupling – Capacitive stimulators consist of a power source and two electrode disks. The disks are attached directly to the skin on either side of the nonunion. A weight-bearing cast can be worn, but it must allow access to the electrodes. The stimulator produces an internal electric field with a frequency of 60 kilohertz, which does not require a high-voltage power source. The device can run on a 9-volt battery and produces a current between 5 and 10 milliamperes for optimum effect. The voltage gradients in the field are relatively small but cover a larger local area compared to direct current stimulation or PEMF. This system is noninvasive and alarms indicate when the electrodes lose contact or the battery is low. These devices are also on continuously during the treatment period.(15–17,33,34,113,114)

Pulsed electromagnetic fields (PEMF) – PEMF stimulators are manufactured in various designs to accommodate the bones being treated. One design consists of two external coils placed parallel to each other and over the nonunion. Other designs have only a single coil. Electromagnetic fields are generated when current flows through the coil. The fields extend at right angles to the coil and penetrate the bone. PEMF stimulators may be used with a cast. Power is delivered to the unit with a rechargeable battery. The electrical fields have a small voltage gradient but over a small tissue area. Stimulation is applied for 8 to 14 hours daily, often at night. These devices are also noninvasive but might not work effectively with internal plate fixation, which could shield the nonunion from the magnetic fields.(11,12,14,27,33,113,115–117)

#### High-energy extracorporeal shock waves (ESW)

Shock waves are large-amplitude compression waves that pass through a fluid. A shock wave is caused by a sudden, violent disturbance of the fluid. For the purpose of medical therapy, the shock wave is directed at a specific site to be treated. The shock waves are not hindered by water or soft tissue but become destructive when they hit high density tissue such as bone. New microfractures and small bone fragments are believed to be formed at the site of a fracture or nonunion. For treatment of nonunions, the shock wave generator and focusing device are enclosed in a water-filled balloon that is placed next to the nonunion. A typical therapy session involves delivery of thousands of shock waves but the patient usually requires only one session,(although some patients may require a second session if the nonunion has not healed after 3 months). Treatments are performed under local or general anesthesia, with each session lasting between 30 minutes and 1 hour. The actual mechanisms of action responsible for shock wave’s effect on fractures and nonunions is unknown, but the short-term destruction of bone tissue may enhance cell proliferation and the production of new bone.(19,118–121)

#### Orthobiologics

Orthobiologics require an invasive surgical procedure for placement in the nonunion site. Included in this group are materials that provide structural support for bone growth stimulated by other means and materials that directly stimulate bone growth.

Osteoconductive matrix materials – Osteoconductive materials provide a three dimensional substance into which capillaries, osteogenic cells, and other tissue can migrate and produce new bone. This material acts only as a scaffold into which the new cells grow. The material is porous and has chemical structures similar to cancellous bone. Calcium sulphate (plaster of Paris) and tricalcium phosphate are biocompatible and resorbable. Hydroxyapatite, a form of calcium phosphate and the principal bone salt, has a structure similar to cancellous bone and provides more support than calcium sulphate or tricalcium phosphate but is not as resorbable.(106,107,122)

Osteoinductive bone graft substitutes – Osteoinduction refers to the induction of osteoblast formation from osteogenic stem cells. The osteoinductive properties of bone tissue are attributed to bone morphogenetic proteins (BMPs), of which there are 14 known types (BMP-2 through BMP-15). These proteins are members of the TGF-β supergene family. Several recombinant human BMPs have been shown to have particularly strong osteoinductive activity in a variety of animal species. These include BMP-2, BMP-4, BMP-5, BMP-6, and BMP-7. When placed in a carrier that provides a framework for bone formation, BMPs are believed to be able to provide the osteoinductive properties lacking in other bone substitutes.(31,34,122–125)

Demineralized bone matrix (DBM) is processed from human bone tissue using a demineralizing agent such as hydrochloric acid. The mineral content of the bone is reduced to below 5% of native levels. The remaining substance is 90% type I collagen and 10% non-collagenous proteins containing a variety of bone growth stimulators (osteoinductive agents such as bone morphogenetic proteins). DBM is used in a number of bone graft substitutes and is both osteoconductive and osteoinductive.(106,107,122)

Osteoprogenitor cells – Bone marrow obtained by aspiration from the iliac crest is a source of osteogenic stem cells that can be placed into a nonunion either by percutaneous injection or by an open surgical procedure. Centrifugation of the bone marrow allows concentration of osteogenic cells and their progenitors in the sample. The FDA has approved a system for collection and processing of bone marrow aspirate for use as a bone graft substitute (Cellect™, DePuy), but its use for treatment of nonunion has not been published in the peer-reviewed literature.(31) In the future, growth factors may be used to stimulate proliferation and differentiation of stem cells.(107,122)

### Evidence Base

We identified 42 articles that potentially met our a priori inclusion criteria and were therefore retrieved. On retrieval, 18 of the 42 articles were found not to meet our inclusion criteria. These articles and the reason for their exclusion are listed in Table D-1 of Appendix D. Fourteen of the 18 studies were excluded because they had less than 20 patients in the study. The remaining four studies were excluded for reasons not related to patient numbers. One study was excluded because it did not examine nonunion fractures, two studies were excluded because they were technical papers and did not report patient data, and one study was excluded because the patient data were reported in another included study.

Having excluded the 18 articles above, 24 studies remained. These studies, which are listed in Table 3, consist of three studies of ultrasound, seven studies of PEMF, four studies of direct current and capacitive coupling, six studies of shock wave, and four studies of orthobiologics. Details of these studies are presented in the tables in Appendix D.

Table 3 Evidence Base for Key Question 6

References | Study Design | N
Ultrasound (see Table D-2)
Mayr et al. 2002(1) | Prospective case series | 100
Nolte et al. 2001(9) | Prospective case series | 29
Mayr et al. 2000(10) | Retrospective case series – registry data | 1317
Pulsed electromagnetic fields (see Table D-3)
Simonis et al. 2003(11) | RCT | 34
Sharrard 1990(12) | RCT | 45
Traina et al. 1991(14) | Retrospective comparison study | 67
Ito and Shirai 2001(116) | Retrospective case series | 30
Adams et al. 1992(126) | Retrospective case series | 54
Garland et al. 1991(27) | Prospective case series | 139
Meskens et al. 1990(117) | Retrospective case series | 34
Direct Current and Capacitive Coupling (see Table D-4)
Scott and King 1994(15) | RCT | 21
Brighton et al. 1995(16) | Retrospective comparison study | 271
Zamora-Navas et al. 1995(17) | Retrospective case series | 22
Cundy and Paterson 1990(18) | Retrospective case series | 37
Shock wave (see Table D-5)
Biedermann et al. 2003(19) | Prospective case series | 73
Rompe et al. 2001(20) | Prospective case series | 43
Schaden et al. 2001(21) | Retrospective case series | 115
Wang et al. 2001(119) | Prospective case series | 72
Vogel et al. 1997(120) | Prospective case series | 48
Valchanou and Michailov 1991(22) | Retrospective case series | 79
Orthobiologics(see Table D-6)
Friedlaender et al. 2001(23) | RCT | 124
Wilkins and Kelly 2003(24) | Retrospective case series | 35
Johnson and Urist 2000(127) | Retrospective case series | 30
Johnson et al. 1992(128) | Retrospective case series | 25

### Quality of Included Studies

Each study was examined for quality according to the USPSTF rating system of research design and internal validity, interpreted for this clinical topic, as described in the Methods section of this report. The rating is included in the evidence tables in Appendix D and will be discussed below for each study. None of the included studies were rated “poor” quality, i.e. “fatally flawed.”

#### Study Design

We identified only four randomized controlled trials (RCT): two for PEMF, one for capacitive coupling, and one for orthobiologics. We included case series in this report based on the prevalent belief that nonunion fractures are not likely to heal without intervention (see discussion in the Background section). Some of the reviewers of the draft of this report preferred to describe these as “self-paired patient controlled” studies – with each patient serving as his or her own control.(5–8) For the purpose of this report, however, we have considered these studies with no separate comparison group to be case series rather than controlled trials.

While declared nonunions are unlikely to heal spontaneously, concomitant treatments (e.g., changes in immobilization of the fracture site or improvements in comorbid conditions) provided in addition to the primary treatment under investigation may contribute to nonunion fracture healing.(129) Of the six studies with a comparison group, five reported nonunion healing in some patients not receiving the treatment under study.

Table 4 Included Studies with Control Groups Treated for Nonunion Fractures Addressing Key Question 6

Reference | N | Duration of Nonunion (weeks) | Prior Treatments | Control Treatment | Time to Healing (weeks) | Healing Rate (%)
Simonis et al. 2003(11) | 16 nonunions | Mean: 123 SD: 74 | Patients had undergone an average of 4.2 prior surgical procedures | Oblique fibular osteotomy followed by a unilateral external fixator with compression | Not reported | 50% (8 of 16)
Friedlaender et al. 2001(23) | 61 nonunions | Median: 68 | Prior autograft: 31% Prior IM rod: 44% | Bone graft | At 36 weeks | 85% (52 of 61)
Brighton et al. 1995(16) | 48 nonunions | Mean: 89.6 Range: 36 – 256 | Prior bone graft: 48% Prior electrical treatment: 50% Metal fixation present: 44% | Bone graft | Not reported | 58% (28 of 48)
Scott and King 1994(15) | 11 nonunions | Mean: 104 Range: 48 – 172 | Patients had undergone an average of 1.8 prior surgical procedures. | Managed conventionally with a plaster cast or brace as was appropriate for the specific fracture. | Study stopped after 26 weeks | None
Traina et al. 1991(14) | 26 nonunions | Mean: 104 Range: 36 – 720 | Patients had undergone an average of 1.4 prior surgical procedures | These patients were treated for unsatisfactory biomechanical conditions (bone loss over 1 cm, inadequate immobilization, non-alignment of bone stumps) which could account for the lack of healing by the most appropriate orthopedic technique. | Mean: 31.2 | 69% (18 of 26)
Sharrard 1990(12) | 25 delayed unions | Mean: 24.2 SD: 4.6 | No prior treatments other than initial fracture treatment (no internal or external fixation) | A full-leg plaster cast was applied. | Healing evaluated at 12 weeks | 12% (3 of 25)

For a case series to be judged a “good” quality study (in terms of internal validity) in this review, it would have to be prospective, to account for all patients treated, to follow at least 80% of patients for the entire study period, to assess radiographic evidence of healing (as well as pain and weight-bearing), to use a blinded or masked assessment method, to report a statistical analysis of results, and to clearly define the interventions employed. There were no case series meeting all of these criteria; four failed to meet one or two of the criteria, and were considered “fair.”(9,20,27,119) The remaining case series were judged to have low internal validity.

#### Comparability of Outcomes

Most of the studies in the evidence base rely on radiographic evidence as the only indicator of nonunion healing. As previously mentioned, Bhandari et al. 2002(2) found that 79% of surgeons use radiographic evidence of cortical continuity as their primary means of defining nonunion fracture healing, but that 42% also used weight-bearing and 37% also used pain on palpation of the fracture site. A combination of radiographic evidence and clinical evidence has been proposed as the best means of judging healing.(12) However, only nine of the 24 included studies combined radiographic evidence with clinical evidence to define nonunion fracture healing. Comparability of outcomes across studies examining the same intervention will be discussed below under each intervention.

### Findings of Included Studies

#### Studies using ultrasound

Three separate studies with a total of 1446 patients reported data concerning ultrasound treatment of nonunions. Specific information on each study is presented in Table D-2. All studies were case series using the Exogen system and examined the responses of multiple bone types. The Exogen system has been approved by the FDA for the treatment of nonunion fractures (see Table B-1).

Nolte et al.(9) examined 29 patients and included both radiographic evidence and clinical assessment in determining healing. Healing rates were compared using Fischer’s exact test for patients grouped by types of fixation in place before and during ultrasound therapy. No differences in healing rates were found for the eight patients treated by casting, 12 patients treated by osteosynthesis, six with intramedullary rods, and three with external fixators. However, even if this analysis were adequately powered to detect a difference, it would not rule out a role for fixation and stabilization in the healing process, only that each method of fixation worked equally well with ultrasound. Not including the 12 patients excluded from their analysis, all 10 tibias healed and four out of five of the femurs, radii, and scaphoids healed. Response to treatment was monitored with clinical and radiographic examinations at 6- to 8-week intervals, and treatment was continued until the treating surgeon declared the nonunion healed. This study was considered fair rather than good quality because it did not mask patient assessment.(9)

Results for 12 patients enrolled but excluded from the analysis are also presented in the article. These patients were excluded for the following reasons: one for lack of compliance, three for early withdrawal, and eight who had undergone surgery within 90 days of receiving ultrasound (an exclusion criteria). Some of the patients who had undergone surgery within the 90-day period prior to use of ultrasound were still considered to be ultrasound “successes.” This could inflate the effect of ultrasound if the prior treatment effect was still ongoing. The healing rate as reported in the study was 86% (25 of 29 nonunions) healed excluding the 12 patients described above. However, if only the eight cases that did not meet the authors’ inclusion criteria are excluded, the analysis yields a 76% rate of healing (25 of 33). The article is not clear about whether the stratified analyses presented were planned before the study began or were post hoc analyses. Among the patients that completed the study, 18 had no treatment other than the initial procedures used to treat the fracture. Fourteen of these patients (78%) healed during the study. All 11 of the patients who received a secondary procedure prior to ultrasound therapy healed.(9)

Mayr et al. examined data on 1317 patients from a registry maintained by the manufacturer of the ultrasound device.(10) Patients were described as having “delayed union” (951 cases) if a fracture remained unhealed for 3 to 9 months following fracture, and “nonunion” (366 cases) if the time since initial fracture was greater than 9 months. Percentage of patients healed and time to healing for delayed union and nonunion in this prescription-based registry were compared to results obtained for 42 patients in the authors’ clinic, but no other validation of the registry is mentioned in the article. The authors found very similar rates of healing and time to healing in their clinic population as in the registry population, based on lack of a statistically significant difference.(10) However, one cannot conclude that two groups are the same based on non-significant results.

Among the nonunions in this study, 314 of 366 (86%) fractures healed, including 105 of 120 (88%) tibias and 57 of 66 (86%) femurs. Among the 951 “delayed unions,” 862 (91%) healed, including 350 of 380 (92%) tibias and 85 of 98 (87%) femurs.(10) Given the requirement that nonunions be diagnosed at 9 or more months following injury (mean 24.9 months), these results suggest that the ultrasound therapy contributed to healing. Of note, the mean time to healing in the nonunion patients was 152 (S.E.: 5.3) days versus 129 (S.E.: 2.7) days in the delayed union group.(10)

The size of the registry population does improve the generalizability of the results; however, retrospective data collection and post-hoc analyses of registry data generally raise concern about potential for bias in patient selection and analysis. Outcome assessments in the Mayr et al. study were not blinded and may not have been consistently applied across all patients. Compliance was not reported, and clinical examination (pain and weight-bearing) was not used as part of the assessment of healing. The study was therefore considered to have low internal validity. The study also failed to consider the effect of concurrent immobilization or other treatments in the assessment of healing rates. While the study provides an interesting overview of healing in a large number of bone types, detailed data (mean ages, numbers of patients in each age, and co-morbidity group, etc.) are not reported.

A translation of Mayr’s other study, published in German after the report on the registry data, was provided to us by one of the reviewers of the draft report.(8) This publication describes 100 patients treated by Mayr with ultrasound.(1) Healing rates were 55 of 64 (86%) for delayed unions, which healed in an average of 142 days, and 31 of 36 (86%) for nonunions, which healed in an average of 171 days. Inclusion of the 21 patients who discontinued treatment reduces the overall healing rate to 86 of 121 (71%). The internal validity of the study was considered low because the outcome assessment was not blinded, pain and weight-bearing outcomes were not reported, and statistical analysis was not reported.

Although the size of the patient populations and the methods of data collection and analysis were very different, Nolte et al.(9) and Mayr et al.(10) reported 86% healing in nonunions of all bone types at an average of 152 days and Mayr et al.(1) reported 86% healing of nonunions in 171 days. Nolte et al.(9) reported that all six patients 65 or older had healed nonunions after treatment, but Mayr et al.(10) analyzed the registry data for an effect of age and reported that the healing rate for nonunions consistently declined from 97% at 20 years to 71% at 70 years.

##### Pre-1990 studies of ultrasound

We identified no pre-1990 clinical studies published in English that describe the use of ultrasound to treat nonunions.

##### Conclusions for ultrasound

Three case series published since 1990 (two prospective and one retrospective) using the Exogen system to treat nonunion in 1446 patients are in general agreement with each other that a high percentage of nonunions healed during ultrasound therapy.(10) While the results of these studies suggest that ultrasound promotes the healing of nonunion fractures, they do not rule out a role for other concurrent treatment procedures—such as stabilization of the nonunion—contributing to the observed effects. The two studies reporting data for patients over 65 are not in agreement as to the effect of age on response to ultrasound treatment.

#### Studies using PEMF

Seven studies published since 1990 with a total of 403 patients reported data concerning PEMF treatment of nonunions. Two of the studies were double-blind RCTs examining only tibial nonunions. They evaluated the use of PEMF for treatment of tibial nonunion in two distinct clinical situations: after extensive surgical intervention in one study(11) and prior to any surgical intervention in the other.(12) One retrospective study with a concurrent comparison group included patients with fractures at multiple sites. One of the case series examined only tibial nonunions, one examined only scaphoid nonunions, and the remaining two examined multiple bone types. Specific information on each study is presented in Table D-3. No device names were reported in these studies. However, personal communications from the manufacturers of PEMF devices have revealed that Sharrard(12) used the EBI Bone Healing System and that Garland et al.(27) used the Orthofix Physio-Stim Bone Growth Stimulator. The FDA has approved these devices and several other PEMF devices for the treatment of nonunion fractures.

Simonis et al.(11) treated 34 patients with established nonunions (>1 year from the initial fracture) and an average of four surgical procedures prior to entering their study. Patients were treated with fibular osteotomy followed by unilateral external fixation and either an active PEMF device or a dummy device for 6 months. Compliance was measured with a hidden timer. Radiological assessment of bone bridging was blinded, but no clinical assessment for pain and function was reported. Simonis et al. reported that 16 of 18 (89%) healed in the active group compared to 8 of 16 (50%) healed in the dummy device group after an average of 15 weeks (unadjusted odds ratio 8.0, 95% CI of 1.5–41, p = 0.02, Fisher’s exact test). However, the lower healing effect seen in the control group may have been due to the larger proportion of smokers randomized to that group (13 of 16) compared to the number in the active group (8 of 18). When the overall results were adjusted for smoking, the association was less strong and not statistically significant (odds ratio 5.4, 95% CI of 0.85 to 34, p = 0.07).(11) Therefore, this study does not provide unequivocal evidence that PEMF promoted nonunion healing above that provided by the surgical intervention.

Sharrard(12) used a full-leg plaster cast on 45 patients with delayed unions. He treated only patients with fractures unhealed after 16 to 32 weeks of treatment with a long-leg plaster cast and no prior surgical interventions other than those required for management of the initial wound and open reduction of the fracture, if necessary. Patients were excluded if they had undergone internal or external fixation, with the exception of two patients with stabilizing pins incorporated into their casts. Patients were also excluded if the fracture gap was >0.5 cm, if the bone was severely atrophic, and if the fracture site showed significant hypertrophy.(12) He randomized patients to active and dummy devices and treated them for 3 months. Clinical assessment as well as blinded radiographic evidence of progression toward union, probable union or full union was reported. Radiographic assessments were made independently by Dr. Sharrard (an orthopedist) and a radiologist. “Progress toward healing” was defined by the radiologist as “a definite change from the earlier films, either with new subperiosteal bone, fuzziness across the fracture site or new bone peripherally across the fracture site.” “Probable union” was defined as “a marked change with thicker denser bone across at least two cortices and fuzziness across the fracture site.” “Full union” was diagnosed when the radiographs showed “dense and extensive new bone formation” across the “fracture site and at least three of the four cortices visible on the two films.”(12) Dr. Sharrard, on the other hand, stated that “I, as an orthopaedic surgeon considered union to be sufficient to cease treatment when continuity was present over at least half the width of the bone, a category regarded by [the radiologist] as “progress to union.”(13) When clinical assessment suggested healing (as judged by absence of motion at the fracture site) but radiographic assessment did not, the radiographic assessment was considered the more reliable indicator. In all cases in which radiographic union was present, movement was absent on clinical exam. Three of 20 in the active group showed full union, two probable union, five progression toward union, and 10 showed no change using the radiographic criteria described above. In contrast, none of the 25 in the dummy device group showed full union, one showed probable union, one showed progression toward union, and 23 showed no change. Clinical assessment indicated that more than half of both groups had no movement of the nonunion fracture and both groups reported reduced pain. There were statistically significant differences in union or progress toward union in favor of the active group as judged by the radiologist (p = 0.002) and by the orthopedist, Dr. Sharrard (p = 0.02).(12) In view of the time to full healing reported in the majority of studies, the 3-month observation period in this study may not be adequate for concluding that PEMF promoted healing beyond that provided by the concurrent surgical intervention. However, Dr. Sharrard did follow these patients for an average of 2 years and his unpublished findings have been provided for inclusion in this report.(13)

Dr. Sharrard regarded the 3-month findings as intermediate outcomes indicating progression towards healing and defined the final positive outcome as healing with no further surgery.(13) During the follow-up period, 17 of 20 (85%) of the original active group healed without surgery, indicating that a number of patients who had not shown progression toward healing in the initial 12-week period went on to heal after the study (and presumably, the treatment) ended. Of the 25 patients who originally received dummy devices, three were lost to followup after the 12-week study and 8 of the remaining 22 patients (36%) healed during the long-term follow-up period without surgery or other intervention, again suggesting that longer periods of observation are necessary for assessing full healing of nonunion. Another 8 patients in the original dummy device group, all of whom were assessed as showing no improvement by 12 weeks, requested an active unit at the end of the 12-week study; 6 of the 8 went on to heal without surgical intervention.(13)

Based on the 12-week data and categorical modeling, Sharrard(12) concluded that patient age was not a factor in treatment outcome. However, this conclusion is based on intermediate outcomes and not on the follow-up data. A similar analysis of age was not reported in Dr. Sharrard’s followup.(13) Dr. Bruce Simon, Director of Research at EBI, the manufacturer of the PEMF device used by Dr. Sharrard, has indicated in a personal communication that their categorical analysis, included in a PMA application to the U.S. Food and Drug Administration, also showed no effect of age, consistent with Sharrard’s findings.(6) EBI did not report a p value but indicated that their findings were in agreement with the p value of 0.23 reported by Sharrard in his published study. These studies may have insufficient sample sizes to find a statistically significant relationship. Sharrard(12) originally planned to recruit 100 patients but had only 45 and EBI did not report their sample size. P values <0.05 are typically accepted as sufficient for rejecting the null hypothesis (i.e., that age has no effect on healing rate), but a p value >0.05 does not prove the null hypothesis. Insufficient evidence to reject the null hypothesis does not imply sufficient evidence to accept it. Therefore, no conclusions as to the effect of age on PEMF treatment of nonunions can be based on these data at this time.

Traina et al.(14) treated 41 patients with PEMF and compared the results to patients treated simultaneously by other means. The average number of prior surgeries was 1.6 per patient in the treated group and 1.4 in the control group, and the average nonunion duration was 1.8 years in the treated group and 2.2 in the control group. The control group (average age of 46) was older than the treated group (average age of 38). Overall, 36 of 41 (88%) in the PEMF group healed as did 18 of 26 (69%) in the control group. However, greater differences in healing rate were seen in the presence of infected nonunions. Non-infected nonunions showed equal healing rates: 20 of 23 (87%) in the treated group and 14 of 16 (87%) in the control group. Infected nonunions healed better in the treated group: 16 of 18 (88%) in the treated group and four of 10 (40%) in the control group (p <0.05). The authors report that the effects of stimulation were apparent within the first 3 months, and they recommend a change in therapy if progression is not observed within that time frame.(14) This study suggests that PEMF may benefit the healing of infected nonunions. However, the groups may not be directly comparable because of differences in age, the types of bone treated in each group, and differences in other patient characteristics. This study was rated low on the internal validity scale for these reasons, as well as for the retrospective data collection and absence of blinded assessment.

Garland et al. 1991(27) reported on a prospective case series that used blinded assessment and therefore had fair internal validity. Internal validity was not considered “good” because of a high dropout rate. One hundred eighty-one patients with various types of nonunions were treated, but only 139 completed the treatments (28% dropout rate). Patients had established nonunions of more than 9 months duration (average of 2.6 years) and averaged two previous surgeries including 131 internal fixations and bone grafting. Immobilization, bracing, and weight-bearing decisions were left to the judgment of the treating physician. Thirty-seven of 50 (74%) tibias, 13 of 15 (87%) femurs, and 10 of 13 (77%) scaphoids healed, but the authors did not report an average time to healing. Other bone types were treated in 10 or fewer patients. The overall reported healing rate was 80% (108 healed out of 135 fractures in the 126 patients with more than 3 hours of PEMF treatment per day). Only 126 patients were included in the healing rate analysis after excluding 42 patients who dropped out before completing the study, and 13 patients who averaged less than 3 hours per day of treatment. With all patients accounted for, the overall healing rate was 57% (108 of 190). When results were stratified by duration of nonunion prior to PEMF treatment (9 – 12 months in 78 nonunions vs. >12 months in 115 nonunions), the authors report that there was no statistically significant difference in healing rates, but data are not provided. In contrast, Brighton’s study,(16) discussed in the next section of this report, describes a predictive model for nonunion healing that indicates a decline in healing rate with increasing duration of nonunion.

In a subgroup analysis of 97 patients at 4 years, 89 (92%) had healed. This study still suggests that PEMF may promote fracture healing in established nonunions given the long duration of the nonunions in the population prior to PEMF therapy. Brighton’s study,(16) discussed in the next section of this report, describes a predictive model for nonunion healing that indicates a decline in healing rate with increasing duration of nonunion.

The remaining three studies of PEMF were case series with various deficiencies in design that resulted in low internal validity. None of these studies reported a statistical analysis that would indicate if their reported rates of healing were statistically significant. Ito and Shirai 2001(116) treated 30 tibial nonunions immobilized in plaster casts. Patients had established nonunions and averaged 1.8 previous surgeries and 1.5 years nonunion duration before PEMF treatment. Twenty-five of 30 cases (83%) achieved bony union in an average of 8.6 months. Adams et al. 1992(126) treated 54 scaphoid nonunions immobilized in a cast. All patients had at least one previous surgery and the average nonunion duration was 2.9 years. Thirty-seven of the 54 (69%) cases healed in an average of 4 months. Since these two studies examined one bone type and used similar treatments for all patients, these studies provide some limited evidence that the treatment, PEMF therapy and cast immobilization, enhances the healing of established nonunion fractures. Meskens et al. 1990(117) treated 34 patients with various types of nonunions but all were immobilized in plaster casts. Patients averaged three prior surgeries and a nonunion duration of just over 3 years. Eleven of 15 (73%) tibias healed in this study, but the average time to healing for this bone type was not reported. Other bone types were treated in 10 or fewer patients. This study provides some limited evidence that PEMF plus cast immobilization may enhance healing in established nonunion fractures of the tibia.

Two of the PEMF studies provided data on older individuals. Garland et al.(27) reported that 18 of 28 (64%) patients over 60 years had healed nonunions compared to 90 of 107 (84%) patients younger than 60 years. Average time to healing for these age groups was not reported. Ito and Shirai(116) reported nonunion healing in two of three patients 65 and over.

##### Pre-1990 studies of PEMF

While we chose to limit included studies to those published since 1990, several reviewiers of our report noted that several studies of PEMF had been published prior to that date, and asked that we provide some additional information on those studies.(57,130) A technology assessment of electrical bone growth stimulation written by ECRI in 1993 (literature search up to 1992) reported an 80% healing rate for long bone nonunions treated by PEMF, including the tibia.(131) We identified 11 clinical studies published between 1975 and 1989 of PEMF treatment of nonunion fractures that evaluated 20 or more patients (see Table 5). All were uncontrolled studies and report healing rates of between 60% and 90%. Orthofix has provided patient registry data collected between March 1986 and December 1989 describing the treatment of nonunions with the Physio-Stim Bone Growth Stimulator (see Appendix E).(132) The data covered 729 patients and 859 fractures. A healing rate of 85% was reported based on radiographic assessment. The registry includes data on 128 patients over the age of 60, but Orthofix was unable to supply us with the healing rates in this subgroup in time for inclusion in this report.(133)

##### Conclusions for PEMF

Seven studies published since 1990 with a total of 403 patients reported data concerning PEMF treatment of nonunions. Two of the included studies were double-blind RCTs using dummy devices and blinded assessment. One RCT examined longstanding tibial nonunions, comparing PEMF with fibular osteotomy and unilateral external fixation to a dummy device, fibular osteotomy, and external fixation. The healing rate was higher in the group receiving PEMF in addition to the other treatment, but was not statistically significantly different after adjustment for confounding by the greater proportion of smokers in the control group.(11) The second RCT compared PEMF and full-leg plaster cast immobilization vs. a dummy device and cast immobilizaton in patients with “delayed tibial union” (failure to heal within 16 – 32 weeks of initial injury while treated with cast immobilization).(12) While radiographic assessments demonstrated significantly greater progression toward healing in the active device group at the end of the 12-week study, longer follow-up prior to further intervention may have altered the difference between the groups. Nonetheless, 17 of 20 patients treated with the active device from the beginning of the study had healed at long-term followup.(13) One nonrandomized study with a concurrent control group demonstrated higher rates of healing in the PEMF group with infected nonunions, but no adjustments were made for differences in patient and fracture characteristics in the two groups.(14) One prospective case series which included patients with nonunions of long duration also reported healing in 57%. The remaining case series showed healing when PEMF therapy was combined with cast immobilization. Studies conducted prior to 1990 were consistent with the more recent studies in terms of healing rates. Overall, these results consistently indicate that nonunions heal in patients treated with PEMF, but the effect of PEMF cannot be separated from the effect of concomitant fracture site stabilization.

Table 5 Pre-1990 Studies of PEMF Treatment of Nonunion Fractures

Reference | N | Bones Treated | Percentage Healed | Average Time to Healing
Krempen et al. 1981(134) | 20 fractures | Multiple bone types, 17 (85%) tibia | 90% | 7 months
Heckman et al. 1981(135) | 149 patients with 153 fractures | Multiple bone types, 94 (63%) tibias | 64.4% | 11.1 months
Bassett et al. 1982(136) | 1007 fractures in a multi-center study | Multiple bone types, 658 (65%) tibia | 77% overall, 82% for tibia | Nonunions healed within 6 to 8 months
Sharrard et al. 1982(137) | 52 patients with 53 fractures | Multiple bone types, 30 (57%) tibia | 72% overall, 87% for tibia | 6 months median
Marcer et al. 1984(138) | 147 patients | Multiple bone types, 102 (69%) tibia | 73% overall, 75% for tibia | Not reported
Dunn and Rush 1984(139) | 37 nonunions | Multiple bone types, 20 (54%) tibia | 81% overall, 80% for tibia | Not reported
Cheng et al. 1985(140) | 50 nonunions | Multiple bone types, 28 (56%) tibia | 62% overall, 78% for tibia | 7 months
Hinsenkamp et al. 1985(141) | 235 nonunions | Multiple bone types, 148 (63%) tibia | 73% overall, 79% for tibia | Not reported
Frykman et al. 1986(142) | 44 patients | Scaphoid nonunions | 80% | 4.3 months
Colson et al. 1988(143) | 32 patients with 33 fractures | Multiple bone types, 22 (67%) tibia | 19 fractures treated with PEMF and surgery healed (100%) and 12 of 14 treated with PEMF alone (86%). Healing in tibia not reported | 6 months for both

#### Studies using direct current or capacitive coupling

Three separate case studies and a single RCT with a total of 353 patients reported data concerning direct current or capacitive coupling treatment of nonunions. Specific information on each study is presented in Table D-4. One retrospective study examined tibial nonunions in separate groups of patients treated with direct current, capacitive coupling, and bone graft. The remaining two case series and the RCT examined multiple bone types. The FDA has approved direct current and capacitive coupling devices for the treatment of nonunion fractures.

The RCT by Scott and King(15) examined only 21 patients with established nonunions treated with an active Orthopak bone-growth stimulator capacitive coupling device (n = 10) or an inactive device (n = 11). In the treated group, 6 of 10 healed in an average of 21 weeks. None of the control group healed after 26 weeks. There were five tibial nonunions of 10 total nonunions in the active treatment group, vs. 10 tibial nonunions out of 11 total nonunions in the control group, which may have negatively affected the healing rates in the control group.

The retrospective comparative study by Brighton et al. 1995(16) used logistic regression analysis to compare tibia healing rates among 167 patients treated with direct current, 56 patients treated with capacitive coupling, and 48 patients treated with bone grafts. The patients treated with electrical stimulation were all placed in casts while the bone graft patients had internal fixation, external fixation, or internal fixation plus cast. The actual healing rates and time to healing were not reported. The different methods of fixation used in the three treatment groups complicates any comparison of results for these three forms of treatment. The logistic regression analysis was described in detail and seems to have been properly constructed using logarithmic transformation of the data. The analysis calculated better than 95% healing with all three treatments when the nonunions were of 10-month duration prior to treatment and no other risk factors for failure to respond to the treatments were present. The risk factors associated with a decline in healing rates included longer duration of nonunion prior to treatment, open fracture, comminuted fracture, prior failed bone graft or prior failed electrical therapy. Patient age was used as a continuous variable in the logistic regression analysis, but any influence age may or may not have on healing was not reported by the authors. Actual healing rates and time to healing that would be useful in comparison with other studies were not reported, except for the patients treated with bone graft. Twenty-eight of 48 (58%) tibial nonunions treated with bone graft healed, but no time to healing was reported.

The remaining two studies, Zamora-Navas et al. 1995(17) and Cundy and Paterson 1990,(18) are also retrospective case series with low internal validity. Zamora-Navas et al. reported that their patients were immobilized with either plaster cast, external fixation, or other procedures, which limits our ability to distinguish the effect of electrical stimulation from these other therapies. This study specifically examined patients with large nonunion gaps (>1 cm, which is wider than is typical for nonunions treated with electrical stimulation). The study did report that 8 of 10 (80%) tibias and 4 of 6 (67%) humeri healed in a average of 26 weeks. Zamora-Navas et al. reported that one 65 year-old patient healed after 42 weeks of treatment and that one 70 year-old patient did not heal after 24 weeks of treatment.(17)

Cundy and Paterson report on their 10-year followup of patients treated with an implanted bone growth stimulator. Forty-four percent of the original patients could not be located, which reduces the validity of the study. All of the 37 contacted patients reported that their nonunions were healed, but six of these patients healed following bone grafting and internal fixation.(18)

In our search of recent meeting abstracts, we identified a single study of at least 20 patients that examined direct current stimulation. This meeting abstract, which was presented at the 2003 OTA meeting, reported that direct current stimulation can be combined with morselized allograft, demineralized bone matrix, and platelet-derived growth factors to treat nonunion fractures.(144) Multiple bone types were treated. Overall, 105 of 109 (96%) nonunions healed.

##### Pre-1990 studies of direct current or capacitive coupling

As with PEMF studies, we were asked by reviewers of our report to provide some additional information on earlier studies of direct current treatment.(5–7,130) A technology assessment of electrical bone growth stimulation written by ECRI in 1993 (literature search up to 1992) reported an 80% to 90% healing rate for tibial nonunions treated by direct stimulation.(131) We identified six clinical studies published between 1975 and 1989 of direct electrical stimulation treatment of nonunion fractures that evaluated 20 or more patients (see Table 6). All were uncontrolled studies and report healing rates of between 40% and 90%. We identified no additional studies of capacitive coupling.

##### Conclusions for Direct and Capacitive Coupling Treatment

We identified four studies published since 1990 with a total of 351 patients treated with direct current or capacitive coupling treatment of nonunions. An RCT examined patients with established nonunions treated with an active capacitive coupling device (n = 10) or an inactive device (n = 11).(15) While 6 of 10 in the active treatment group healed in an average of 21 weeks compared to none of the control group, the inclusion of twice as many tibial nonunions in the latter group may have negatively affected the healing rates. One retrospective comparative study examined tibial nonunions in separate groups of patients treated with direct current, capacitive coupling, and bone graft.(16) This study used logistic regression analysis to estimate better than 95% healing with all three treatments when the nonunions were of 10-month duration prior to treatment and no other risk factors for failure to respond to the treatments were present. Risk factors predicting slower healing rates included longer duration of nonunion prior to treatment, open fracture, comminuted fracture, prior failed bone graft or prior failed electrical therapy. Patient age was used as a continuous variable in the logistic regression analysis, but any influence of age on healing was not reported in the study. In the remaining two studies, one specifically examined patients with large nonunion gaps (>1 cm), which is thought to be a contraindication for electrical stimulation.(17) Therefore, the results of this study are not generalizable to other types of nonunions. The other study reported on the 10-year followup of patients treated with an implanted bone growth stimulator, but 44% of the original patients were not located, reducing the validity of the reported results.(18) An additional six case series published between 1975 and 1989 had reported healing rates between 40% and 90%. Overall, these studies consistently demonstrate healing during treatment with direct current and capacitative coupling, but the effect of these therapies cannot be separated from the effect of concomitant immobilization of the fracture site.

Table 6 Pre-1990 Studies of Direct and Capacitive Treatment of Nonunion Fractures

Reference | Device | N | Bones Treated | Percentage Healed | Average Time to Healing
Forsted et al. 1978(145) | Direct | 20 fractures | Multiple bone types, 17 (85%) tibia | 90% | 7 months
Paterson et al. 1980(146) | Direct | 84 patients | Multiple bone types, 72 (86%) tibia | 86% overall, 88% for tibia | 4 months
Zichner 1981(147) | Direct | 57 fractures | Multiple bone types, 16 (28%) tibia | 93% overall, 100% for tibia | 5.3 months
Connolly 1981(148) | Direct | 49 fractures | Multiple bone types, 34 (69%) tibia | 69% overall, 76% for tibia | Not reported
Ahl et al. 1984(149) | Direct | 23 fractures | Multiple bone types, 14 (61%) tibia | 43% overall, 50% for tibia | 6.4 months
Zhong-xing et al. 1986(150) | Direct | 42 nonunions | Multiple bone types, 20 (48%) tibia | 88% overall, 85% for tibia | Not reported

#### Studies using shock waves

Six separate studies with a total of 430 patients reported data concerning shock wave treatment of nonunions. All were case series and examined multiple bone types. The Osteostar (Siemens, Germany) was used in two studies, the MFL 5000 Lithotriptor (Dornier Medizintechnik GmbH, Germany) in one study, the OssaTron (High Medical Technology, Switzerland) in one study, and the remaining two studies did not report a device name. Five of the studies were conducted in Europe and one was conducted in Taiwan. Specific information on each study is presented in Table D-5. Shock wave devices have not been approved by the FDA for use in treating nonunion fractures. Unlike the continuous or intermittent pattern of biophysical stimulation used in electrical stimulation, PEMF therapy, and ultrasound therapy, shock wave therapy only requires one or two short treatments.

Biedermann et al. 2003(19) in a prospective case series classified nonunions as long bone or other, hypertrophic or atrophic, and delayed union or nonunion. Results were reported according to these categories, limiting comparison to other studies. All patients were immobilized with cast or brace. The authors reported that hypertrophic nonunion healed better than atrophic nonunions—21 of 34 (62%)—hypertrophic nonunions and 11 of 22 (50%) atrophic nonunions) but did not report whether this was a statistically significant difference. Rompe et al.(20) prospectively examined tibial and femoral nonunions. Treatment with casting and limited weight-bearing was continued following shock wave therapy. Unlike most case series, this study used blinded assessment of radiographic evidence and clinical examination. The study reported 31 of 43 (72%) patients with bony bridging and full weight-bearing by an average of 4 months: 13 of 19 (68%) of tibias healed; 18 of 24 (75%) femurs healed; 19 of 24 (79%) nonsmokers healed; and 12 of 19 (63%) smokers healed, but the authors did not report any statistical analysis of these results. Schaden et al. 2001(21) reported a retrospective case series in which the nonunion sites were immobilized in casts or splints if implanted devices showed signs of loosening. The study reported that 26 of 34 (76%) tibias, 14 of 21 (67%) scaphoids, and 11 of 12 (92%) femurs healed during the study period but does not report the time to healing. The follow-up period lasted from 3 months to 4 years (average of 18 months), which does not allow for an accurate accounting of the time needed to judge whether the shock wave therapy was successful or not. Schaden has updated his findings in an abstract presented at the February 2005 annual meeting of the AAOS. After a maximum followup of 5 years, 175 of 204 patients (86%) achieved bony union.(151) Wang et al. 2001(119) prospectively examined patients treated with shock wave therapy who were treated with crutches and partial weight-bearing for lower extremities and slings for upper extremities. The study reported results separately for 3, 6, and 12 months but not on an intent-to-treat basis. Within the groups of patients remaining in the study at each time period, the rates of healing for both hypertrophic and atrophic nonunions increased with each follow-up period. This could be an actual effect of treatment or it may indicate that the dropouts were unhealed patients. The authors do not provide an explanation. The study does indicate that atrophic nonunions may have a diminished response to shock wave therapy compared to hypertrophic nonunions, but no statistical analysis was performed to test this association. Vogel et al. 1997(120) prospectively examined patients treated with shock wave therapy followed predominantly by immobilization in a cast. Healing rates for individual bone types were not reported, which prevents comparison with other studies or determining if one bone type healed better than another. At a mean of 3.4 months (range of 2 to 9 months), 29 of 48 (60%) patients showed complete healing. Valchanou and Michailov 1991(22) retrospectively examined patients treated by shock wave followed mostly by cast immobilization. The study did not report if consecutively treated patients were included, which leaves open the possibility that patients were selectively chosen for this study or that dropouts were not reported. Seventy of 79 (85%) patients showed radiographic evidence of bone bridging, but the average time until healed was not reported. The value of this study is diminished by the lack of reporting, specifically whether the patients were consecutive and the time needed to heal.

One of the studies provided data on older individuals. Rompe et al.(20) reported that three of four patients older than 65 years showed healing in an average of 4 months. One patient of 73 years did not heal.

##### Pre-1990 studies of shock wave

We identified no pre-1990 clinical studies that describe the use of shock wave to treat nonunions.

##### Conclusions for shock wave

Six separate case series published since 1990 with a total of 430 patients reported data concerning shock wave treatment of nonunions of multiple bone types.(19–22) Five of the studies were conducted in Europe and one was conducted in Taiwan; shock wave devices have not been approved by the FDA for use in treating nonunion fractures. These case series reported healing rates between 50% and 80%, but the effect of shock wave therapy cannot be separated from the effect of immobilization in these uncontrolled studies.

#### Studies using orthobiologics

Four separate studies, all published since 1990, with a total of 214 patients reported data concerning the use of orthobiologics to treat nonunions. One study was an RCT comparing OP-1 Implant (Stryker Biotech) to fresh bone autograft in the treatment of tibial nonunions.(23) Stryker Biotech was granted a humanitarian device exemption (HDE) by the FDA for the use of OP-1 Implant as an alternative to autograft in recalcitrant long bone nonunions in situations where the use of autograft is not feasible and alternative treatments have failed (see Table B-1). The other three studies were case series. One examined the use of AlloMatrix Injectable Putty (Wright Medical Technology) in nonunions in multiple bone types.(24) AlloMatrix Putty contains demineralized bone matrix (Allogro from AlloSource), carboxymethylcellulose, and OsteoSet, which is calcium sulfate. AlloMatrix Putty is cleared by the FDA only for “bony voids or gaps that are not intrinsic to the stability of bony structure” (see Table B-1) and is therefore not directly cleared for use in nonunion fractures. Its use in treating nonunion fractures could therefore be considered “off label.” The remaining two studies involve the use of composite allograft material prepared by the study authors. Specific information on each study is presented in Table D-6.

Friedlaender et al. 2001(23) presented their findings from a randomized controlled trial comparing a bone graft substitute, OP-1 Implant, with standard bone grafting in the treatment of tibial nonunions. Bone autografting is the standard of care for treating tibial nonunion fractures. This procedure requires bone to be harvested from the iliac crest (hip), and morbidity at the harvest site is common. Implantation of OP-1, which contains recombinant human OP-1 (rhOP-1), is an alternative to bone autografting that eliminates the need for harvesting bone. Recombinant human OP-1 is a bone morphogenetic protein (BMP-7) embedded in a collagen matrix. It is surgically implanted at the site of nonunion to encourage bone to form across the fracture site.

In this study, patients underwent intramedullary rod fixation in addition to the grafting procedure. The internal validity of this study was rated as “fair” only because the patient could not be blinded to treatment. Autogenous bone grafting requires removal of bone from the patient’s hip; therefore, this procedure cannot be blinded. However, radiographic assessment of bone bridging was blinded. Key outcomes reported in this study included the ability to bear weight on the treated leg, pain at the fracture site, radiographic evidence of healing, retreatment surgery, surgical complications, and treatment-site complications. In general, new technologies are accepted only if they are superior to the standard of care. However, when OP-1 Implant is used, morbidities that normally occur at the bone autograft harvest site are avoided. Therefore, to be clinically superior to autografting, OP-1 Implant does not need to have superior healing ability; it only needs to have equivalent healing ability. A statistical comparison, commonly referred to as a test for “noninferiority,” can be performed to detect equivalence of two interventions. However, the authors of this report only performed the standard statistical testing to determine whether one treatment is superior to the other.

Friedlaender et al. reported that the healing rates after 9 months were 39 of 63 (62%) for OP-1 and 45 of 61 (74%) for bone graft based on three radiographic views.(23) This difference was not statistically significant. Combined clinical success, defined as full weight-bearing, less than severe pain at the fracture site on weight-bearing, and no retreatment, was 51 of 63 (81%) for OP-1 and 52 of 61 (85%) for bone graft; this difference was not statistically significant. The need for surgical retreatment was low in both groups, 3 of 60 (5%) for OP-1 and 6 of 61 (10%) for bone graft, again not a statistically significant difference. The bone graft group did have significantly more postoperative osteomyelitis (p = 0.002), 2 of 60 (3%) for OP-1 and 13 of 61 (21%) for bone graft.(23) However, pin tract infection associated with the use of an external fixator prior to placing a reamed tibial nail (as was done in both groups) is a risk factor for subsequent infection. Without controlling for this possible confounder it is difficult to interpret the unusually high incidence of osteomyelitis in the autograft group.(152) Atrophic nonunions were significantly more prevalent in the OP-1 group (41% vs. 25%, p = 0.048), and there was a greater proportion of smokers in the OP-1 group as well (74% in the OP-1 group vs. 57% in the autograft group, p = 0.06).(23) These conditions would be expected to hinder the healing process and may have reduced the likelihood of success with the OP-1 Implant.

A meeting abstract provides additional information on OP-1 treatment of long bone nonunions.(153) Forty nonunions in patients with an average of three prior surgeries were treated. Thirty-one of the nonunions (78%) showed radiographic evidence of healing in a mean of 5.9 months of treatment. Further assessment of this study must await full publication.

Wilkins and Kelly(24) reported a retrospective case series of the use of AlloMatrix Injectable Putty in treating nonunions in multiple bone types. The nonunions were also treated using standard internal/external fixation techniques. The article does not report if patients are being treated for the first time or the duration of the nonunions prior to the AlloMatrix Putty treatment. Without this information, comparisons to other studies are difficult. The study also does not report whether all consecutively treated patients were included or if dropouts occurred during the treatment period. The reported healing rate was 30 of 35 (85%) in an average of 3.5 months, but healing rates per bone type were not reported. A meeting abstract reporting on the use of demineralized bone matrix (DBM) in treating nonunions found significant problems.(25) In this study of 41 nonunions, 54% healed but high rates of wound drainage and subsequent deep infection reduced the effectiveness of DBM in treating nonunions. A second meeting abstract reported on the use of a DBM and bone marrow aspirate composite graft to treat nonunions.(26) Fourteen nonunions were treated and radiographic union was achieved in 75% of patients in an average of 9.3 months.

The remaining two studies were retrospective case series from the same laboratory that examined the use of a composite allograft with partially purified human bone morphogenetic protein (hBMP) to treat nonunions of the femur in one study, Johnson and Urist 2000(127), and multiple bone types in the other, Johnson et al. 1992.(128) The earlier study was intended to show that the composite allograft with active human BMP could enhance healing in nonunion fractures that had failed to heal after other procedures such as electrical stimulation and surgical procedures. In addition to the allograft, 22 of 25 patients underwent internal fixation and 7 of 25 received adjunctive bone grafting. Twenty of 25 (80%) nonunions healed after the first implantation of the composite graft in an average of 6 months (range of 3 to 14 months). Four of the five failures healed after revision of the failed fixation, indicating that fixation may also have contributed to the observed healing effect of treatment.(128)

Johnson and Urist 2000(127) looked at healing in 30 femoral nonunions after treatment with the composite allograft and various other treatments. Thirteen patients received additional autogenic cancellous bone graft to the intercalary segmental defect.

Twenty-six patients were implanted with a fixed angle blade plate to stabilize and lengthen the femur. The remaining patients had intramedullary nails. As with the earlier study from this laboratory, the precise role of the allograft in the healing process cannot be distinguished from the other procedures. The study reported that 24 of 30 (80%) femoral nonunions healed with an average time of 6 months and a range of 3 to 9 months.

Only the two studies of composite allograft with hBMP reported data for individuals 65 and over. In the study examining only nonunion of the femur, seven of eight older patients healed within 4 to 6 months.(127) In the other study, all five patients over 65 (three tibias and two humeri) healed.(128)

##### Pre-1990 studies of orthobiologics

We identified no clinical studies of orthobiologics for treatment of nonunion published prior to 1990.

##### Conclusions for orthobiologics

Four separate studies published since 1990 with a total of 214 patients reported data concerning the use of orthobiologics to treat nonunions. One study was an RCT comparing BMP-7, OP-1 Implant (Stryker Biotech) to fresh bone autograft in the treatment of tibial nonunions. Stryker Biotech was granted a humanitarian device exemption (HDE) by the FDA for the use of OP-1 Implant as an alternative to autograft in recalcitrant long bone nonunions where use of autograft is not feasible and alternative treatments have failed. Patients in both groups underwent intramedullary rod fixation in addition to the autograft or OP-1 grafting procedure.(23) The internal validity of this study was rated as “fair” only because autogenous bone grafting requires removal of bone from the patient’s pelvis; consequently, patients could not be blinded to treatment. However, radiographic assessment of bone bridging was blinded. The study found similar healing rates in the two groups. A noninferiority statistical analysis should be performed to determine whether OP-1 Implant in conjunction with internal fixation was not inferior to autogenous bone graft in the treatment of tibial nonunions. Assuming the analysis demonstrates noninferiority, this single study would need to be replicated by other investigators before OP-1 is considered an effective substitute for autogenous bone grafting. The absence of the morbidity associated with harvesting of autogenous bone for grafting is a distinct advantage; therefore, additional studies would only need to demonstrate noninferiority as well.

The other three studies of orthobiologics were retrospective case series. One examined the use of AlloMatrix Injectable Putty (Wright Medical Technology) in nonunions in multiple bone types.(24) AlloMatrix Putty, which contains demineralized bone matrix (Allogro from AlloSource), carboxymethylcellulose, and OsteoSet (calcium sulfate), is cleared by the FDA only for “bony voids or gaps that are not intrinsic to the stability of bony structure” and is therefore not directly cleared for use in nonunion fractures. The publication did not report prior treatment or the duration of the nonunions prior to the AlloMatrix Putty treatment. Without this information, interpretation of the results is difficult. The remaining two studies were retrospective case series from a single laboratory that examined the use of a composite allograft with partially purified human bone morphogenetic protein (hBMP) to treat nonunions of the femur in one study, and multiple bone types in the other. As with other case series, the precise role of the composite allograft in the healing process cannot be distinguished from the other procedures used to stabilize the limbs. Two recent meeting abstracts describing studies utilizing DBM indicated healing rates of 54% and 75% respectively, but one found high rates of wound drainage and subsequent deep infection.(25,26) Additional studies are needed to understand the role of DBM in treating nonunions at this time.

### Concluding Remarks

What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

After searching the literature published since 1990, retrieving references, and applying our inclusion/exclusion criteria, we identified 24 published studies of bone growth stimulators and orthobiologics. Four of the studies were RCTs, two were retrospective comparison studies, seven were prospective case series, and the remaining 11 were retrospective case series. Thus, the overall quality of the evidence for each type of intervention is for the most part low, and few of the studies can actually be used to distinguish the effect of the device or orthobiologics agent from the additional treatments these patients received. While some view case series of patients treated for nonunion as “self-paired, patient controlled” studies, the occurrence of healing at late timepoints in some patients receiving other therapies (e.g., cast immobilization) made us hesitant to view the studies in this way. Two RCTs of PEMF therapy indicate that patients treated with PEMF had healing of nonunions, but the results from one study did not reach statistical significance after adjusting for confounding, and the other was only randomized for the initial 12 weeks of treatment and observation.(11,12) One prospective case series,(27) a retrospective series with a comparison group,(14) and three retrospective case series also demonstrated healing with PEMF treatment, but the effect of PEMF could not be separated from the contribution of the immobilization procedures or casting.(11) The RCT of treatment with a capacitative coupling device demonstrated higher rate of healing in the active treatment group, although the number of tibial nonunions in the comparison group may have negatively affected the results in that group.(15) The remaining RCT, Friedlaender et al.,(23) indicates that OP-1 Implant may substitute for autogenous bone graft in the treatment of tibial nonunions in patients also being treated with reamed intramedullary nail fixation, but a noninferiority statistical analysis is needed to show that OP-1 (along with internal fixation) is not inferior to autogenous bone graft, and additional studies are needed to replicate the results. Case series studies of ultrasound and shock wave therapy report healing of nonunions with these therapies, but individual study quality limits the strength of the evidence and the effects cannot be separated from those of concomitant treatments. There is some indication from case series that DBM preparations are also useful, but additional studies are needed to understand the role of DBM in treating nonunion.

The studies’ generalizability to the Medicare population was poor with few studies either reporting results separately for individuals 65 years of age or older or analyzing results by age groups. It is commonly argued that there is no change in healing response with increasing age,(5–7) but whether this holds true across the lifespan (even in the absence of comorbid conditions that predispose to impaired healing) is not evident from the literature we examined. The higher prevalence of osteoporosis in older adults complicates the management of nonunion by reducing the likelihood of successful stabilization with internal fixation.(28,29) Whether the results of treatments in younger adults can be generalized to persons of advanced age is not entirely clear, but reporting of outcomes separately for older patients in studies of nonunion treatments would provide useful information.

The authors gratefully acknowledge the guidance of our orthopedic consultant, Mitchel B. Harris, M.D., F.A.C.S. Dr. Harris is the Chief of the Orthopaedic Trauma Service at Brigham and Women’s Hospital in Boston, Massachusetts.