# BACKGROUND

## Fracture Healing and the Development of a Nonunion

Bone tissue is composed of a matrix of 25% water, 25% protein (mostly collagen), and 50% mineral salt (calcium and phosphorus salts and calcium hydroxyapatite) and a small number of bone cells spread throughout the matrix. The components of mature bone marrow, bone tissue and periosteum have distinct composition and function but are interdependent. Bone has three mature cell types that are responsible for the production and maintenance of bone matrix: osteoblasts, osteocytes, and osteoclasts. Osteoblasts are derived from stem cells and progenitors, some of which are capable of forming other mesenchymal tissues such as cartilage, fat, fibrous tissue and muscle under appropriate conditions.(31) Osteoblasts form new bone matrix by secreting collagen fibers and initiating the calcification process. This matrix contains the mineral which provides the tensile strength of bone, as well as type I collagen and other organic components which give bone flexibility.(32) As they mature, some of the osteoblasts survive within the new matrix and develop into osteocytes. Osteocytes maintain the cellular activity of the bone. Osteoclasts, which are derived from a stem cell population derived from hematopoietic stem cells, are responsible for removing old worn-out bone matrix.(31) Compact or dense bone (also called cortical bone) provides support and resists stress. Cancellous bone (also called trabecular or spongy bone) is found adjacent to the joint surfaces of bone and lining the cavity of long bones. Bone is a dynamic tissue that constantly replaces old bone matrix with new bone matrix.(33)

When a bone is fractured, the blood vessels across the break are ruptured. Blood clots around the site of the fracture and forms a fracture hematoma. Because of the disrupted blood supply, many of the bone cells in the fracture site die. The fracture hematoma becomes the center of an inflammatory response that removes cellular debris and prepares the tissue for healing. The inflammatory phase of healing, which constitutes approximately 10% of total healing time, is characterized by a proliferation of various cell types and the infiltration of new blood capillaries into the fracture site.(32)

Transforming growth factor-beta (TGF-β) seems to play a key role in initiating and stimulating the phases of fracture healing that occur after the formation of the fracture hematoma. TGF-β is abundant in the bone matrix and in platelets. It controls the proliferation of osteoblasts that lay down collagen fibers in the fracture gap and of osteoclasts that remove the fractured bone particles. The rate at which repair proceeds and the composition of the tissue formed varies depending on the type of bone fractured (i.e., cancellous bone vs. cortical bone), the severity of injury to soft tissue and vascular supply, the stability of the fracture site, the degree of separation of the fracture surfaces, and a variety of host factors (both local and systemic).

Five to ten percent of all fractures do not heal (nonunion) or heal very slowly (delayed union).(34) Bones heal at different rates, leading to different standards for the time by which healing is expected. In addition, for a given anatomic location, the type of fracture is another factor in setting the expectation for time to healing. Court-Brown et al. evaluated several grades of closed and of open tibial fractures, finding a mean healing time of 12 weeks in the simplest closed fractures (n = 38) but a mean of 56 weeks in the most severe open fractures (n = 12).(3)

Initial trauma to the blood supply of the bone medulla and periosteum, a source of osteogenic cells, may be the cause of nonunion in the majority of cases.(30) Several potential surgical and non-surgical causes for impaired healing may also be involved.(30,34,35) The surgical causes include inadequate stability of the fracture, an excessive residual fracture gap, infection introduced at the time of surgery , and excessive stripping and damage to the periosteum. Non-surgical causes include persistent contamination of the fracture site from the time of an open (compound) injury, an injury with bone loss leading to a lack of apposition of the fracture fragments, insufficient blood flow to the soft tissue at the fracture site, malnutrition, chronic illness, smoking, or use of medications (e.g., non-steroidal anti-inflammatory drugs and corticosteroids) that interfere with healing.

Many orthopedists consider nonunion to be a cessation of the healing process, which, if left untreated, will never heal. Our search did not identify long-term studies supporting this assumption, but it appears to be based on extensive clinical experience. For example, Mayr et al. stated that “The orthopedic literature is quite clear in stating that all processes have stopped in a nonunion, and healing can only be initiated by another procedure since no spontaneous healing will take place.”(10) This study and another by Nolte et al. on ultrasound treatment of nonunion relied on the assumption that without intervention, a nonunion will not heal. Both studies used patients as their own controls.(9)

## Overview of Treatment Decisions for Nonunion

The treatment options for nonunions are designed to enhance the cellular processes that lead to fracture repair. The exact approach depends on the condition of the fracture, surrounding soft-tissue damage, the patient’s preferences and comorbid conditions and the physician’s preference and experience.(36)

The algorithm (Figure 1) illustrates an overall approach to choice of therapy for nonunion. The science of bone healing is still evolving, and the algorithm presented represents an oversimplification of the underlying biological processes.(4,32,37,38) Nonetheless, several reviews and texts organize the decision-making process around these basic principles.

Once nonunion has been diagnosed, the presence or absence of infection is a key determinant of treatment. In general, implantation of new hardware for stabilization may need to be delayed until antibiotic therapy and surgical debridement bring the infection under control (step 1). In some cases, previously implanted hardware must be removed. An external fixation device is sometimes used for stabilization of the fracture site in this setting. Once infection is quiescent, the fracture site is reassessed for nonunion and the subsequent steps followed.

The stability of the fracture site (step 4) may range from none (as in the case of freely movable bone fragments) to fairly rigid (in the case of fragments with good interdigitation and stiff fibrous or cartilaginous tissue across the site).(31) For simplicity, the algorithm is divided into those noninfected nonunions in which lack of stability appears to be the major problem (step 5) and those in which the biological processes necessary for bone formation have failed (step 13). In practice, both instability and biologic deficits frequently coexist, but one may be the dominant issue for initial nonunion treatment decisions.

The assessment of stability of the fracture site is partially based on the radiographic appearance of the fracture. If a nonunion is accompanied by exuberant callus formation, it is generally assumed that the biologic processes are intact, but that excessive motion or strain at the fracture site has disrupted the healing process. Breakage or loosening of hardware from the stress of motion at the fracture site may be seen on x-ray. Motion at the fracture site on clinical examination may be present.

If the acute fracture has been treated with closed reduction and external support (step) (e.g., cast, brace or external fixator), internal fixation may be necessary to achieve alignment and stability of the nonunion site (step 9). If internal fixation was used in prior fracture management but stability was not achieved (step 11), the hardware may be replaced or stabilization may be supplemented with either additional internal or external fixation (step 12). For example, an intramedullary nail used in the management of a tibial or femoral shaft fracture may be removed and replaced with a nail of greater diameter. A variety of devices and techniques are utilized to stabilize ununited fracture sites, with the choice of hardware and technique determined in large part by the characteristics of the fracture site, the patient, and the surgeon’s experience.

Figure 1 Overview of Treatment Decisions for Nonunion

At the other end of the spectrum is the nonunion with good alignment and stability, but no visible callus and a persistent gap between fracture fragments on x-ray. In this situation, a defect in the biological processes is presumed (step 13). Bone resorption occurs at the bone ends and fibrous or fibrocartilaginous tissue may fill the gap, or a synovial capsule may form around the bone ends, creating a pseudoarthrosis.(32) It is often stated that such nonunions, referred to as atrophic nonunions, are relatively avascular, but a study by Reed et al. disputes this assertion. The authors used an antibody labeling technique to quantify vascularity in biopsies of hypertrophic and atrophic nonunions. The study was adequately powered to detect a 10% difference in vascularity at the p <0.05 level and it did not demonstrate a significant difference in median vessel counts.(39) Nonetheless, it is generally observed that disruption of the blood supply, either by the initial injury or by subsequent surgery, impairs fracture healing and increases the risk of nonunion. Although much has been learned in recent years about the biological processes involved in fracture healing, there are still gaps in understanding the reasons for failure of healing.(40) Clinical experience has shown that fresh bone autograft, which contains viable cells and growth factors, will stimulate fracture healing in the nonunion site (step 17). In current practice, bone graft obtained from the patient’s iliac crest or from a bone site near the fracture (e.g., use of tibial bone in distal femur nonunion) is the most common treatment for failure of the healing process.(32) Unfortunately, retrieval of the autograft may cause significant morbidity in terms of blood loss, pain and risk of infection. In some cases, these risks may outweigh the potential benefits (steps 15 and 18). Bone marrow harvested by aspiration also contains osteogenic cells and has been used in the treatment of nonunion. It can be delivered by percutaneous or open routes to the nonunion site, with time to union and volume of callus formed related to the number and concentration of progenitor cells (measured as fibroblast colony-forming units) in the aspirate.(41) Comparisons of bone marrow grafting to standard surgical bone autografting and to the FDA-approved bone morphogenetic protein (BMP-7), OP-1, were beyond the scope of this report.

Untreated allografts are highly likely to provoke an immune response that leads to graft rejection (i.e., excessive local inflammation and subsequent resorption); therefore, allografts are treated by freezing, freeze-drying or irradiation. Allografts of cancellous, cortical or corticocancellous bone are employed in specific situations, but the efficacy may vary depending on the processing, handling and preservation (step 18).

Given the morbidity associated with autogenous bone harvesting, an alternative treatment for atrophic nonunions with comparable rates of healing and comparable time to healing as bone grafting would provide patients with a valuable option, assuming the new treatment does not also have significant adverse effects. Proposed and current alternatives to bone autografts will be discussed thoroughly under Key Question 6 in the body of this report.

In practice, achieving stability of the fracture site is equally important when bone grafting is performed. Cancellous bone grafts, while rich in growth factors and inflammatory mediators, do not provide mechanical stability; additional measures are generally employed to stabilize the site. Corticocancellous grafts provide some additional support, but unless a graft with retained vasculature is used, the graft will be resorbed and remodeled, decreasing its strength for some time. Some authors refer to the process of reaming the marrow of a long bone (such as the femur or tibia) for placement of an intramedullary nail as an “internal cancellous bone graft.”(42,43) Rodriguez-Merchan notes that while reaming and nailing disrupt the vascular supply to the endosteum, a periosteal vascular reaction develops which stimulates bone formation.(38) Finally, amputation may be an acceptable alternative in some situations, particularly when associated injury to soft tissue and peripheral nerves would leave the limb nonfunctional or persistently painful even with bony union.

## Anatomic Location of Nonunion Fractures

The National Center for Health Statistics’ National Health Interview Survey for 19921994 provides information on the frequency of fractures in the United States.(44) Of a total of 5,946,000 fractures per year, the average annual number of lower leg fractures (tibia, fibula, and ankle) in the United States was 581,000. Approximately 10% of tibial fractures result in nonunions.(30) The majority of nonunion fractures (62%) occur in the tibia, while 23% occur in the femur, 7% in the humerus and 7% in the forearm.(36) Motor vehicle accidents are the most common cause of tibial shaft fractures, and are more likely to produce open high energy fractures.(3) Advances in fracture treatment in other bones have led to fewer healing problems while advances in emergency medicine have reduced the number of lower limbs that would have been amputated. However, the salvaged lower limbs are more likely to be severely injured and have a higher rate of nonunion than fractures at other sites.(36)

## Relevance of Nonunion Fractures to the Medicare Population

Data from the 2002 Health Care Utilization Project (HCUP) Nationwide Inpatient Sample (NIS) estimate that more than 13,000 individuals 65 years of age and older were hospitalized for the treatment of nonunion fractures.(45) This age group was 36% of the total patient population treated as inpatients for nonunion fractures. Medicare was the payer for 14,658 individuals, 38% of the total. Publicly-available HCUP data (HCUPnet) for nonunions are not subdivided by bone type, but data are available on the frequency of fractures in various bone types. Fractures of the humerus accounted for 32,623 discharges for individuals 65 years and older and this age group accounted for 49% of discharges with this diagnosis.(46) Likewise, the principal diagnosis of fracture of the shaft and distal portions of the femur was given in 23,061 discharges and fractures of the tibia/fibula in 13,953, with the older patients comprising 40% of discharges with the former and 20% of discharges in the latter instance. Fractures of the proximal femur (hip fractures) led to hospitalization of 273,161 individuals 65 years and older and this age group accounted for 89% of hip fractures.

Buckwalter et al. state that the rate of healing declines with increasing age only up to the point of skeletal maturity, then remains relatively constant.(32) As stated previously, epidemiologic studies of fracture healing rates would be useful for determining when an ununited fracture is evidence of delayed healing; such studies would also be useful for examining rates of healing with advanced age. While it is generally believed that fractures in older adults normally heal at the same rate as those in younger individuals, age-related changes in the bone tissue could theoretically affect fracture healing in the elderly and increase the likelihood that nonunions will occur. Several mechanisms have been hypothesized. Osteoblasts and chondrocytes may not be able to fully synthesize matrix proteins because of a decline in protein synthesis capacity or the proteins produced may not be fully functional. The osteogenic stem cells may decline in number and reduce the capacity to produce new osteoblasts. The osteoblasts may have a shorter life span and produce less new bone matrix. The overall decline in cortical and cancellous bone mass and an increase in microarchitectural damage with age may contribute to fracture incidence and delay healing. The bone mass loss with age may be related to a diminished response of bone tissue to mechanical loading stress which would ordinarily stimulate the removal of old bone and the production of new bone. Diminished bone turnover may also be due to a disruption in the communication and coordination between osteoblasts and osteoclasts.(47–51)

It has also been postulated that trophic hormones, growth factors, and cytokine concentrations may decline in the circulation or these substances may not be produced in sufficient quantities during the inflammatory phase of fracture healing. Street et al. examined the effect of age on angiogenesis following fracture.(52) They measured concentrations of vascular endothelial growth factor (VEGF) and platelet-derived growth factor (PDGF) in fracture hematoma and systemic circulation in 16 patients under 40, and in 16 patients over 75 years of age who were undergoing open reduction internal fixation (ORIF) of isolated closed fractures. Serum levels of these cytokines were similarly elevated in both groups, although concentrations of PDGF were lower in the fracture hematoma of the older subjects. However, plasma from patients in both groups induced endothelial cell proliferation in vitro to a similar extent. These authors conclude that impairment of angiogenesis is unlikely to play a role in delayed healing with advanced age.(52)

The higher prevalence of osteoporosis in older adults complicates the management of nonunion by reducing the likelihood of successful stabilization with internal fixation.(28,29) Whether the results of treatments in younger adults can be generalized to persons of advanced age is not entirely clear, but reporting of outcomes separately for older patients in studies of nonunion treatments would provide useful information.