# Additional Data Supplied by Reviewers

Additional unpublished data was supplied by Orthofix, Inc. and EBI regarding the use of PEMF for treatment of nonunion. The data from Orthofix supported a PMA. The information from EBI provides followup to the study by Sharrard.(12)

1. Reference: Orthofix - PMA P850007 / S20 February 7, 2000

Citation: | Physio-Stim® Bone Growth Stimulator – Patient Registry Data
Intended Use | ⊠Non-union fracture □Osteotomy □Lumbar spinal fusion □Other: ___________
Stimulation Type | □Internal Electrical Stimulation ⊠External Electrical Stimulation
Commercial Device Name(s) | Physio-Stim®
Overall Study Design | □Prospective, Double-Blind Randomized Controlled Trial □Prospective □Retrospective ⊠Other: [underlined: Patient Registry]
# Patients | 729 patients with 859 fractures (62% male, 38% female)
Age | <18 years to 70+ years (mean 44 years; 73 patients = 60+ years, 55 patients = 70+ years)
Selection Criteria | Inclusion:; - Patients diagnosed by their physician to have a nonunion fracture after 2 months post-injury (range 2 months to more than one year); - Physio-Stim device prescribed with documented timing of the intervention.; Exclusion:; - Unknown treatment outcome; - Fracture sites other than extremities.
Prior Surgery? | Forty-eight percent of patients had one or two (or more) previous procedures (i.e., internal / external fixation, bone grafting).
Methods | After FDA approval of the device, and while long-term safety and efficacy data were being collected, Orthofix kept a Registry of patients wearing the device for fracture nonunion. The Registry of physician-reported outcomes was tabulated and represents post-market use of the device from the time of approval to the completion of the four-year followup (March 1986 through December 1989). The Registry database includes patient age at the time of treatment, gender, diagnosis, date of injury, fracture location, previous surgical procedures, model number, and treatment start date. Device safety and effectiveness data were collected from the treating physicians including treatment completion date, outcome assessment and date, as well as complications or adverse events. The results are the fracture healing outcomes of 729 patients with one or more nonunion fractures (totaling 859 fractures). Physicians recorded their observations of radiographic and clinical healing on a form returned to Orthofix.
Success/Failure Criteria (Radiographic, Clinical, other) | Radiographic: Success = union/healed Failure = nonunion/not healed.
Results | Radiologic Effectiveness:; - 729 fractures healed (85%).; Clinical Effectiveness:; - Return to normal function; Other Effectiveness:; - None; Morbidity (infection, amputation, permanent loss of limb function); - No untoward effects.
Strengths | The clinical experience within the Physio-Stim Patient Registry to heal nonunion fractures is statistically comparable to that demonstrated in the Physio-Stim prospective, multi-center, controlled clinical trial supporting the premarket approval. These Registry data offer additional support because they are derived from a larger patient population than the original clinical trial, with greater numbers of individual fractures in each site location.
Weaknesses | None identified.

TELEPHONE “UPLANDS”

(0742) 664918 140 MANCHESTER ROAD,

SHEFFIELD

510 SDL

15th June 1993

- Naomi Aronson, Ph.D.
  Blue Cross Association
  676 North St. Clair Street
  Chicago, Illinois 60611

Dear Dr. Aronson:

I have recently had the opportunity to review the comments developed by Blue Cross/Blue Shield’s Medical Advisory Panel relative to its evaluation of electrical bone growth stimulation. There appear to be several issues concerning our double blind study of delayed union as published in the British JBJS (herein referred to as Sharrard Study) and its implications concerning the benefit in delayed unions.

In the December 29, 1992 memorandum to Electro-Biology, Inc. (EBI), the Blue Cross/Blue Shield Association raised several issues concerning the Sharrard Study (in context of the article). Specifically, these are:

1. Does radiographic evidence of healing after 12 weeks, and intermediate outcome, predict health outcomes such as healing and need for subsequent surgery?
2. Why was statistical significance shown with radiographic assessment (after 12 weeks) but not with clinical assessment (e.g. movement at the fracture site, pain, and tenderness)? How does one assimilate this into the overall technology assessment when making a determination of efficacy?
3. How do differences in the radiologist’s and my evaluation of radiographic assessment affect its significance and overall interpretation.

With respect to question #1, whether positive radiographic evidence at 12 weeks (an intermediate outcome) predicts final health outcomes, it is important to understand that the purpose of our published study was to determine radiographically in a double-blind investigation whether PEMF had a positive biological effect. Based on years of clinical experience, it is apparent to orthopedists (as it will be to your Panel upon further review of the data provided herein), that intermediate positive radiographic assessment has a positive correlation to final clinical success.

First, let me share with you the fact that long-term follow-up data has indeed been developed which provides patient endpoints an average of 2 years after PEMF treatment had been initiated. This follow-up was the result of continued diligence on the part of myself and my colleagues to collect and evaluate long-term outcome data. It appears to us that this follow-up data responds to your Association’s concerns regarding health outcome endpoint several years after initiation of therapy. The following tables and graphs establish, from a perspective of final health outcomes, that the PEMF treatment of delayed unions delivered a statistically significant advantage over placebos.

For purpose for this analysis, positive [underlined: intermediate] outcome is defined as the 12 week radiographic assessment of either having healed or showing progress towards healing. Positive [underlined: final] outcome is defined as those that healed with no further surgery as noted an average of 2 year (median 15 months) after treatment was initiated.

In the Sharrard Study, at 12 weeks the intermediate outcome of PEMF treatment was shown to be highly significant (p=0.009). On a combined basis, a positive intermediate outcome (radiographic progress as determined by either me or the blinded radiologist, Barrington) was noted in 65% of the patients (13 of 20) in the active group. By comparison, the control group (using identical criteria) evidenced only 32% of the patients (8 of 25) reported with a positive intermediate outcome.

Of importance is the fact that in the control group, 64% (14 of 22 patients) required further intervention, as opposed to only 15% (3 of the 20 patients) in the active group. Given the significance (p=0.00134), it is important to reiterate that 85% (17/20) of the treatment group went on to heal without surgery versus only 36% (8 of 22) in the control group (3 patients lost to follow-up).

Finally in the control group patients opting for an active unit (8) at study termination 75% (6 of the 8 people) went on to heal with PEMF while only 25% (2 of the 8) went on to surgery. All 8 patients requesting active PEMF at the Study’s termination had been assessed by both the independent radiologist (Barrington) and me as failures at the 12 week mark.

Details of the final outcome analysis are as follows:

Table I Delayed Union Study Long-Term Follow-Up - Final Outcome Report (Mean 2 years, median 15 months)

| ACTIVE (n = 20) | CONTROL (n = 25)
Healed With No Further Surgery | 17 (85%) | 8 (32%)
Surgery | 3 (15%) | 8^*^ (32%)
PEMF (Requested Live Units > 12 Weeks No Further Surgery) | - | 6 (24%)
Lost To Follow-Up > 12 Weeks | - | 3 (12%)
TOTAL | 20 | 25

* Two patients requested live - healed after surgery.

In reviewing the long-term data (Table II) one sees a 90% correlation of positive intermediate outcome (PIO) (measured radiographically) to positive final outcome (PFO). One can be relatively confident that positive radiographic assessment after 12 weeks, an intermediate outcome, is an accurate predictor of positive final outcome (healing with no further surgery).

A detailed analysis of my radiographic assessment and that of the independent radiologist (Barrington) on the same group and the correlation to positive final outcome is as follows:

Table II Delayed Union Study Correlation Between Positive Intermediate Outcome (PIO) and Positive Final Outcome (PFO)

| | POSITIVE OUTCOME
ASSESSMENT | GROUP | INTERMEDIATE | FINAL
Sharrard | Active | 11 | (10/11) 91%
| Control | 8 | (6/7^**^) 86%
Barrington | Active | 10 | (9/10) 90%
| Control | 2 | (2/2) 100%
Combined^*^ | Active | 13^*^ | (12/13) 92%
| Control | 8^*^ | (6/7^**^) 96%
| Both Groups | 21 | (18/20^**^) 90%

* Combined Assessment Progressing (P) or Healed (H) at 12 weeks by either Barrington and/or Sharrard.

** One patient (#37) with a positive intermediate outcome at 12 weeks was lost-to-follow-up.

One clinical fact is clear in both groups which is that there is a 90% correlation of positive intermediate outcome to positive final outcome. Thus, it is safe to conclude that positive intermediate outcome (radiographic measurement at 12 weeks) is an accurate predictor of positive final outcome (healing with no final surgery).

This correlation of positive intermediate and positive final outcome is graphically presented in the following figure:

Figure 1 Delayed Union Study Correlation Between Positive Intermediate Outcome (PIO) and Positive Final Outcome (PFO)

Question 2: Why was statistical significance shown with radiographic assessment (after 12 weeks) but not with clinical assessment (e.g. movement at the fracture site, pain, and tenderness)? How does one assimilate this into the overall technology assessment when making a determination of efficacy?

The Panel’s second question, related to the statistical significance shown with radiographic assessment (after 12 weeks) but not with clinical assessment (movement at the fracture site, pain and tenderness) clearly focus in on the Panel’s concerns about final health outcomes. Clinical measurements at 12 weeks while providing some valuable clinical insight, are not good evaluative criteria given both their unreliable nature and intermediate status. For example, while movement at a fracture is indicative of failure of union, absence of movement may not necessarily be a reliable indicator of successful union.

Clinical assessment is helpful, but not conclusive at the intermediate point (12 weeks) in the study. Positive radiographic assessment is indeed a better preferred predictor of positive final outcome as shown in the long-term follow-up data provided.

With this issue in mind, it is understandable that there may be some difficulty in reconciling differences in the two assessment methods (radiographic and clinical). Therefore, the final health outcomes status in the data already provided presents BCBSA with a more concise picture of the technology’s efficacy rather than intermediate assessments alone.

Question 3: How do differences in the radiologist’s and my evaluation of radiographic assessment affect its significance and overall interpretation?

The Panel’s final question asks, how do differences in the radiologists and my evaluation of radiographic assessment effect their significance and overall interpretation. Fundamentally, we do not see a difference in the evaluations.

Given the radiographic criteria and techniques used in the trial, an objective assessment was possible. This is particularly true since both the radiologist and I were blinded as to radiographic origin until grading was completed.

Barrington, as a radiologist, considered union in absolute terms required continuity at 4 cortices. I, as an orthopaedic surgeon considered union to be sufficient to cease treatment when continuity was present over at least half the width of the bone, a category regarded by Barrington as progress to union.

It is relevant to note that all those patients were regarded by me as having united, subsequently healed all 4 cortices, but were not necessarily receiving any further treatment, either by a plaster immobilisation or PEMF treatment.

An analysis of the patients Barrington and I determined (radiographically) as having a positive intermediate outcome confirms this statement.

In examining (Figure 1A.) the treatment group, I evaluated 11 of the 20 patients as having a positive intermediate outcome. Assessments by the independent radiologist identified 10 patients as having a similar status. There was substantial agreement on a patient by patient basis with a total of 8 patients common in both blinded assessments. The evaluation (both the radiologist and mine) were similar (90% and 91% respectively) in the portion of patients going on to positive final outcome.

Figure 1A Active Group

In the control group at 12 weeks (figure 1B), I evaluated 8 of the 25 patients (32%) as having a positive radiographic assessment. Barrington identified 2 patients as having a similar positive intermediate outcome. Both of his 2 cases were contained in the group of 8 patients I determined favourable assessments on. Respectively, 86% (6/7) and 100% (2/2) of these cases went on to have positive final health outcomes.

Figure 1B Control Group

* One patient (#37) with a positive Intermediate outcome at 12 weeks was lost to follow-up.

Again, it is important to note that in the control group, the patients I gave positive assessments to which went on to heal, contained the 2 patients to which Barrington gave similar assessments.

In either case, both the radiologist and I had relatively equal accuracy in terms of the portion of patients with positive intermediate outcomes that went on to positive final outcome.

Given the fact that we were both blinded as to the radiographic origins until assessment was complete, this is a significant statement concerning the overall accuracy of both of our intermediate findings.

Given this review, let me offer the following:

- Positive intermediate outcomes (as measured radiographically at 12 weeks) strongly correlate to positive final outcomes.
- Intermediate clinical assessments are not good evaluative criteria, given their unrealistic nature and intermediate status.
- Upon closer analysis, there is no fundamental differences in the radiographic assessments given by Barrington and me.

I agree that the important evaluative criteria for your assessment should be founded on final patient outcome. The data contained herein supports the use of PEMF in achieving the desired patient outcome (healing without further intervention).

Given the techonology’s proven biological effect and positive contribution to patient health outcomes, PEMF therapy which should be made available to physicians as an alternative to other interventional treatment irrespective of time. In general, PEMF treatment of difficult ununited fractures has proven to be as successful as traditional noninvasive fracture management and as efficacious as surgical intervention.

Given the costs and potential risks of surgery, PEMF should be considered as a viable treatment option for orthopaedists treating difficult fractures.

Thank you for having taken this opportunity to review this data.

Sincerely,

W.J.W. Sharrard, M.D., Ch.M., FRCS

cc: EBI Medical Systems, U.S.A.

D-1-3

A DOUBLE-BLIND TRIAL OF PEMFS FOR DELAYED TIBIAL UNION - CLINICAL FOLLOW-UP. J. Sharrard, Sheffield S10 5DL, England.

In 1990, the results of a double-blind trial of pulsed electromagnetic fields (PEMFS) for delayed union of tibial fractures was published (J Bone Joint Burg [Br] 72B, 147-55), based on radiographic evidence of union after 12 weeks of treatment by plaster immobilization with PEMFS compared with treatment by plaster immobilization alone. The radiological outcome was determined blindly either by myself or by a radiologist colleague. My own orthopaedic assessment had, as its endpoint, radiological evidence of union sufficient to allow treatment by immobilization to cease; in the active group, treated by PEMFS, 11/20 showed good progress to union compared with 8/25 controls. The radiologists assessment had, as its endpoint, purely radiographic evidence of bony union; in the active group 10/20 showed union or good progress to union compared with 2/25 controls. If the results in the two assessments are combined, progress to union was present in 13/20 (65%) in the active group and 8/25 (32%) in the control group, a highly significant result (p = 0.009) and indicating that PEMFS do influence bone healing assessed radiologically. A positive radiological result is, however an intermediate result. To determine whether radiographic evidence of healing after 12 weeks was able to predict a final outcome of successful fracture union with restoration of bone function without the need for surgical treatment, long-term clinical data were collected and analyzed. After the end of the study, the choice of further treatment was left to individual surgeons, depending on the condition of the patient. Some patients were allowed to mobilize; 8 patients who had previously received placebo treatment, requested active PEMF treatment; other were treated by bone grafting or other surgical means. The clinical condition of all the 45 patients who engaged in the trial was reviewed at an average interval of 2 years (median 15 months) after the initiation of treatment in the trial. Three patients, all of them in the control group, were lost to follow-up. Healing without surgical treatment occurred in 17/20 (85%) of the active treatment group compared with 8/20 (36%) in the control group (p = 0.00134). Of the 8 patients in the control group who opted for PEMFS treatment at the end of the double-blind study, 6/8 went on to heal without surgery and 2/8 required surgical treatment. The aim of treatment of delayed union or non-union of a fracture by PEMFS is to enhance union by conservative management. This end-result study confirms that PEMFS significantly influence the final outcome of fracture union and can be regarded as an alternative, or, in complex or infected fractures, as preferred treatment to surgical management.

D-1-4

EFFECT OF PULSED ELECTROMAGNETIC FIELDS (PEMF'S) ON BONE FORMATION AND BONE LOSS DURING LIMB LENGTHENING: A PRELIMINARY REPORT. K.S. Eyres and M. Saleh. University Department of Orthopaedics, Sheffield, England.

We have studied prospectively the effect of pulsed electromagnetic fields (PEMF's) on bone formation and disuse osteoporosis sustained during limb lengthening in a double-blind study. Over an eighteen month period, 7 males (mean age 13 years, range 11 to 19 years) and 6 females (mean age 12 years, range 9 to 19 years) randomly received either an active or a dummy unit. Limb lengthening was performed by the Villarubbias technique with a unilateral external fixator system (Orthofix or Sheffield fixator) in 11 patients (85%) and a circular frame system in the remaining two patients (Ilizarov and Sequoia respectively). Bone density measurements were made using dual energy X-ray absorptiometry (DXA) with a specially modified low-threshold analysis programme.

7 patients (2 males and 5 females) received 'active' coils and 6 patients (4 males and 2 females) received 'dummy' coils. Although there was no significant age difference between the two groups (14.4 years and 13.6 years respectively), 10 segments (8 tibial and 2 femoral) were lengthened in the 'active group' compared to only 8 segments (6 tibial and 2 femoral) in the 'dummy group'.

Whereas there was no significant bone loss detected in patients treated with active coils until 2 months after surgery (reduced by 10%±2% control values), marked losses occurred earlier in the patients treated with dummy coils (reduced by 23%±3% and 33%±4% after one and two months respectively; p<0.0001). These difference were greater at twelve months after surgery (reduced by 87%±4% and 46%±5% respectively; p<0.0001). Although there was no significant effect on new bone formation with active PEMFs, there was a significant reduction in disuse osteoporosis. Further study with PEMF's of different waveform is required to assess their effect on bone formation.

D-1-5

THE TREATMENT OF OSTEONECROSIS OF THE FEMORAL HEAD WITH PEMF. R.K. Aaron^1^ and B.A. Pethica^2^.

^1^Orthopaedic Research Laboratory. Brown University, Providence, RI 02906 USA. ^2^Columbia University, New York, NY 10012 USA.