# Evidence Tables for Key Question 6

Table D-1 Excluded Studies for Key Question 6

Reference | Type of device or orthobiologic | Reason for exclusion
Jones et al. 2005(166) | Orthobiologics – hBMP was prepared by the authors | Study examined a single patient with a chronic nonunion of a proximal pole fracture of the scaphoid treated by curettage of the nonunion, single K-wire fixation, and implantation of 50 mg of human BMP followed by 12 weeks of cast immobilization. Excluded for having less than 20 patients.
Delloye et al. 2004(167) | Orthobiologics rhBMP-2 (Genetics Institute) and rhBMP-7 (Osigraft, Stryker) | Study examined 5 patients treated with bone resection, rhBMPs, and allograft for malignant bone tumor. Excluded for having less than 20 patients.
Lerner et al. 2004(165) | Ultrasound Exogen | Study examined 17 patients treated with surgical skeletal stabilization and low-intensity pulsed ultrasound for delayed unions of the long bones associated with high-energy fractures. Excluded for having less than 20 patients.
Luchetti 2004(160) | Orthobiologics Carbonated hydroxyapatite (Norian SRS) | Study examined 6 patients treated with corrective osteotomy and carbonated hydroxyapatite for malunited distal radius fracture. Excluded for not being nonunion fractures.
Pigozzi et al. 2004(164) | Ultrasound Exogen | Study examined 15 patients treated with low-intensity pulsed ultrasound for fracture nonunions at various sites. Excluded for having less than 20 patients.
Saltzman et al. 2004(168) | Pulsed electromagnetic fields EBI Bone Healing System | Study examined 19 patients treated with PEMF for delayed unions after foot and ankle arthrodeses. Excluded for having less than 20 patients.
Nishikawa et al. 2003(169) | Orthobiologics No name provided, the bone paste has been available in Japan since 2000 | Study reported on use of calcium phosphate paste and endoscopic surgery to treat delayed unions and nonunions. Technical paper, no patient data.
Kloen et al. 2002(170) | Orthobiologics | Study examined 21 patients with a delayed union or nonunion to determine the presence of BMPs during the development of a fracture nonunion. Technical paper, no treatment data.
McLee et al. 2002(158) | Orthobiologics Bone substitute (OsteoSet-T, Wright Medical Technology) | Study examined 16 patients treated with debridement, surgical stabilization, and medical grade alpha-hemihydrate calcium sulfate impregnated with tobramycin antibiotic for infected nonunions of long bones. Excluded for having less than 20 patients.
Ikeda et al. 1999(171) | Shock wave – custom made | Study examined 6 patients treated with a custom-made extracorporeal shock wave generator for delayed or nonunion fractures. Excluded for having less than 20 patients.
Rosenthal et al. 1999(172) | Orthobiologics Demineralized bone implants prepared by the authors | Study examined 8 patients treated with debridement, surgical fixation, and demineralized bone implants for fracture nonunions. Excluded for having less than 20 patients.
SattarSyed et al. 1999(173) | Pulsed electromagnetic fields – custom made | Study examined 19 patients treated with pulsed electromagnetic fields for delayed or nonunion of long bones. Excluded for having less than 20 patients.
Wilkins et al. 1999(159) | Orthobiologics Combination of AlloGro (AlloSource) and OsteoSet now marketed as AlloMatrix (Wright Medical Technology) | Study examined 11 patients treated with a combination product of bioassayed, demineralized bone matrix (AlloGro) and calcium sulfate pellets (OsteoSet) for long bone nonunions. Excluded for having less than 20 patients.
Abeed et al. 1998(174) | Capacitively coupled electrical stimulation – device not named | Study examined 16 patients treated with capacitively coupled electrical stimulation for long bone nonunions. Excluded for having less than 20 patients.
Frankel 1998(175) | Ultrasound Exogen | The data for patients with nonunion fractures is more completely reported in a later publication.(10)
Meng-Hai et al. 1996(176) | Orthobiologics – hBMP were prepared by the authors | Study examined 16 patients treated with debridement, internal fixation, and a mixture of bovine bone morphogenetic protein and plaster of Paris for femoral shaft nonunions. Excluded for having less than 20 patients.
Holmes 1994(177) | Pulsed electromagnetic fields – no device name | Study examined 9 patients treated with pulsed electromagnetic fields for delayed unions and nonunions of the fifth metatarsal. Excluded for having less than 20 patients.
Schleberger and Senge 1992(178) | Shock wave | Study examined only 4 patients.

Table D-2 Included Studies of Ultrasound Treatment of Nonunion Fractures Addressing Key Question 6

Reference | Study Design / Purpose / USPSTF Study Quality Rating | Intervention / Outcomes | Demographics | Results | Comments
Nolte et al. 2001(9) | Prospective Case series Purpose: Evaluate the effect of low-intensity ultrasound for the treatment of established nonunions in a consecutively enrolled patient population from various trauma departments. Level II-3 Internal validity criteria: fair; 1. yes; 2. yes; 3. yes; 4. no (outcome assessment not blinded); 5. yes; 6. yes; 7. yes | Sonic Accelerated Fracture Healing System (Exogen) Patients applied the device for a daily 20-minute treatment in their homes. Compliance was defined as the device being used 75% of the time. Immobilization (cast, wiring, internal or external fixation) was continued according to previous treatment. Treatment was continued until the treating surgeon declared the nonunion healed. Bones treated: 5 femurs, 10 tibias/ fibulas 1 humerus, 5 ulnae/ radii 5 scaphoids, 1 ankle 1 clavicle, 1 metatarsal Outcomes: Nonunions were considered clinically healed when pain was absent and weight-bearing did not cause pain, or normal limb function had returned. Radiographic evidence of bone bridging. Patients were examined at regular 6 to 8 week intervals. | n = 41 nonunions in 39 enrolled patients, 29 patients completed the study; 4 patients were excluded for lack of compliance or early withdrawal, 8 nonunions in 7 patients were excluded because there was less than 90 days from last operative procedure to ultrasound therapy. Mean age of 47 years with a range of 18 to 90 years. Sex: 12 F 17 M Inclusion: nonunion fracture (minimum of 6 months post fracture) and healing had not progressed for a minimum of 3 months before ultrasound treatment, and surgery was not currently an option. Exclusion: less than 90 days from last operative procedure. 16 patients were smoking or had stopped smoking, 2 infected nonunions. Initial treatments: 8 conservative treatment 14 osteosynthesis 5 intramedullary nail 2 external fixation Secondary procedures: 6 bone graphs (only one with previous conservative treatment) 4 intramedullary nail 2 external fixation | Healing was demonstrated in 86% of patients (25 of 29) with an average healing time of 152 days. Statistically significant (p <0.0001) when compared to an assumed rate of 5% healing for the prior failed treatment period. One patient was noncompliant and not used in the analysis of results but was included in the intent-to-treat analysis. Age and method of fixation were not a factor in healing rate (no statistically significant differences between age groups or type of fixation used with the ultrasound therapy). Hypertrophic (83% healed) and atrophic/oligotrophic (88%) healed at the same rate, no statistically significant difference. Smoking did reduce healing rate (p = 0.05). 10 of 10 (100%) tibias, 4 of 5 (80%) femurs, 4 of 5 (80%) radii/ulnae, and 4 of 5 (80%) scaphoids healed, 1/1 (100%) humerus healed. The clavicle and metatarsal healed; the ankle did not. According to the authors, the intent-to-treat analysis showed 80% healing (33 of 41 cases healed). No statistical significance reported for intent-to-treat analysis. However, the authors added the eight cases of the excluded group who had surgery within 90 days of ultrasound treatment to the healed cases which could inflate the ultrasound results. These eight cases should not have been enrolled in the study and should not be considered. Therefore, on an intent-to-treat basis 25 of 33 healed (76%). 14 of the 18 (78%) patients with no secondary procedures prior to ultrasound therapy healed within an average of 156 days. All 11 of the patients who received a secondary procedure prior to ultrasound therapy healed. | 6 of the patients were 65 years of age or over. All 6 patients showed healed nonunions. Study reported individual patient data which allowed abstraction of data for patients 65 and over.
Mayr et al. 2002(1) | Prospective Case series Purpose: determine the effectiveness of low-intensity ultrasound treatment on nonunions. Level II-3 Internal validity criteria: low; 1. yes; 2. yes; 3. no (outcome assessment not blinded); 4. yes; 5. yes; 6. no (did not report pain or weight-bearing); 7. no (no statistical analysis is reported) | Exogen Patients applied the device for a daily 20-minute treatment in their homes. Patients were removed from the study for inadequate compliance. 64 Delayed unions and 36 nonunions treated: 2 clavicles 5 humeri 12 radii/ulnae 16 scaphoids 14 femurs 44 tibias 2 fibulas 2 other Outcomes: Healing rate and time to healing. Bone healing was determined by radiology methods. No specific follow-up periods were used in this study. | n = 100 (not including 21 patients who were excluded for discontinuing treatment) Mean age of 44 years with a SEM of 2 years. Sex: 37 F 63 M Inclusion: delayed union (120 days post-fracture) and nonunion (240 days post-fracture) fractures. Bone maturation, clinical stability of the fracture, vitality of the fragment ends, freedom from infection, no change in therapy within 90 days of ultrasound therapy. Exclusion: infection, instability, defect pseudarthrosis, change in therapy within 90 days of ultrasound therapy, fracture gap covered by ultrasound reflective surface. Initial and prior treatments: 29 patients with one or more spongioplasties; 41 of 44 tibia patients had prior surgery with instrumentation. | 55 of 64 (86%) of delayed unions healed in an average of 142 days. 31 of 36 (86%) of nonunions healed in an average of 171 days. Statistical analysis was not reported. % healed: 12 of 16 (75%) scaphoid 9 of 14 (64%) femur 43 of 44 (96%) tibia Scaphoid fractures healed better with initial lower arm cast. Smoking habits did not affect healing rates. | Healing rates were not analyzed by age groups, therefore the relevance of this study to the Medicare population is unknown. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Mayr et al. 2000(10) | Retrospective Case series – registry data Purpose: to evaluate registry data on the effects of ultrasound treatment on nonunions. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. no (outcome assessment not blinded); 4. yes; 5. yes; 6. no (did not report pain or weight-bearing); 7. no (no statistical analysis is reported) | Sonic Accelerated Fracture Healing System (Exogen) Patients applied the device for a daily 20-minute treatment in their homes. Compliance was not reported. Delayed unions/nonunions treated: 38/ 10 clavicles 54/ 48 humeri 52/ 22 radii 43/ 0 ulna 79/ 24 scaphoids 98/ 66 femurs 380/ 120 tibias 27/ 0 fibula 39/ 0 ankle 84/ 18 metatarsals 26/ 20 feet 31/ 38 other. Healing rate and time to healing. Bone healing was defined as 3 cortices bridged in 2 x-ray planes or trabecular bridging of at least 80% of the fracture in the case of cancellous fractures such as scaphoid fractures. No specific follow-up periods were used in this study. | n = 1317 Age and sex information were not reported. Inclusion: delayed union (3 to 9 months post-fracture) and nonunion (9 months post-fracture) fractures. Exclusion: not reported. Healing rates were assessed for renal disease, vascular insufficiency, diabetes, osteoporosis, and local infection. Initial and prior treatments: delayed union – 442 surgery (average of 1.3 operations), 507 conservative nonunions – 213 surgery (average of 1.7 operations), 153 conservative. Concurrent fixation or other treatments not reported. | 91% of delayed unions healed in an average of 129 days. 86% of nonunions healed in an average of 152 days. Statistical analysis was not reported. % healed – delayed unions/ nonunions: 95% / 80% clavicle 76% / 69% humerus 94% / 95% radius 81% / ---% ulna 94% / 100% scaphoid 87% / 86% femur 92% / 88% tibia 96% / ---% fibula 92% / ---% ankle 96% / 78% metatarsal 91% / 90% foot 97% / 89% other | Healing rates were analyzed by age groups. Peak incidence of delayed and nonunions occurred between 30 and 50 years with an additional peak at age 70 for delayed unions. Healing rates declined with age. Up to age 70 the healing rate for delayed unions was 89% to 99%, but after age 70 the rate dropped to 85%. For nonunions, the healing rate consistently declined from 97% at 20 years to 71% at 70 years. The report provides a great deal of analysis especially with regard to the effect of age and co-morbidities on healing rates but without reporting statistical significance. However, only the overview of the analysis is provided and detailed data (mean ages, numbers of patients in each age and co-morbidity group, etc.) are not reported.

Table D-3 Included Studies of Pulsed Electromagnetic Fields Treatment of Nonunion Fractures Addressing Key Question 6

Reference | Study Design / Purpose / USPSTF Study Quality Rating | Intervention / Outcomes | Demographics | Results | Comments
Simonis et al. 2003(11) | Prospective double-blind randomized trial with placebo controlled device Purpose: determine the effect of pulsed electromagnetic stimulation on the treatment of established nonunions. Level I Internal validity criteria: fair; 1. no (method of randomization not reported); 2. yes; 3. yes; 4. yes; 5. yes; 6. no (did not consider pain and weight-bearing); 7. yes | Device name not reported. Prior to randomization, all patients were given an oblique fibular osteotomy, followed by a unilateral external fixator with compression (active treatment). Treatment group received electrical stimulation from an active device. A pulsed electric current was delivered through two large external coils applied directly over the fracture and in contact with the skin. The control group received an identical device but current was passed through a small secondary coil not in contact with the leg. Both groups used the devices for a minimum of 14 hours a day and remained strictly non-weight-bearing. Treatment lasted for 6 months. Bones treated: Tibia only; 16 atrophic and 18 hypertrophic. Outcomes: Radiological signs of bone bridging: loss of fracture gap, cortical bridging, trabecular bridging. Followup of 6 months. | n = 34 Mean of 32 years with a range of 16 to 61. Sex: F4 M 30 Inclusion: tibial shaft fractures un-united at least 1 year after the initial fracture, no metal implant bridging the non-union gap, no radiological progression of fracture union in the 3 months prior to PEMF treatment. Patients were not excluded for active infection. Exclusion: none reported. 21 of the patients were smokers. Initial and prior treatments: Patients had undergone an average of 4 surgical procedures before presentation in the clinic. 23 open fractures, 30 from high velocity road traffic accidents, 6 infected, 16 atrophic, 18 hypertrophic. | 16 of 18 (89%) active treatment fractures healed in an average of 15.3 weeks (10 to 20 weeks). Only 8 of 16 (50%) dummy treatment fractures healed. Because of an imbalance in smoking habits between groups, a comparison was made for smokers and for non-smokers separately, and then an overall significance level was obtained using logistic regression. 13 of 16 patients in the control group were smokers and 8 of 18 patients in the active group were smokers. The unadjusted odds ratio comparing the active to dummy group was 8.0 (95% CI of 1.5–41, p = 0.02. Fisher’s exact test). When the overall results were adjusted for smoking, the association was weaker and not statistically significant, odds ratio of 5.4 with 95% CI of 0.85 to 34, p = 0.07. Smokers had a lower healing rate (75% active and 46% dummy) but was not statistically different from nonsmokers. Further adjustments for the number of previous surgical procedures did not change the odds ratio. | This study has limited relevance to the Medicare population because none of the patients were 65 years or over. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Sharrard 1990(12) | Prospective double-blind randomized controlled trial Purpose: To provide evidence of the true effect of pulsed electromagnetic fields on delayed union tibial fractures by comparing immobilization and active electromagnetic stimulation with similar immobilization and dummy stimulation in a double-blind trial. Level I Internal validity criteria: good; 1. yes (the method of randomization was not reported in the article, a personal communication from EBI indicated that an acceptable randomization procedure was used); 2. yes; 3. yes; 4. yes; 5. yes; 6. yes; 7. yes | Device name was not reported in the publication. A personal communication from EBI indicated that the device used in this trial was the EBI Bone Healing System.(130) A full-leg plaster cast was applied. The active device pulsed current through coils. Patients were instructed to bear no weight on the cast and to use the device for 12 hours a day. Treated for 12 weeks. Bones treated: all tibia. Outcomes: Radiological signs of bone bridging. Assessment was blinded to treatment group. Clinical assessment based on fracture movement, pain, and tenderness. All patients were assessed at 12 weeks. | n = 45; 20 active and 25 control Active group: mean age of 35 years with a range of 18 to 84. Control: mean age of 45 years with a range of 18 to 76. There was a significant difference in the age distribution. Sex: Active group - F6 M14, Control group - F7 M18 Inclusion: 18 years or older with a fracture of the tibial shaft, closed or compound, not less than 5 cm from the ankle or knee, which had not united after at least 16 weeks and not more than 32 weeks of treatment (immobilization in a long-leg plaster cast required). After reduction, the fracture ends must be apposed over at least 50% of their surface, to be in acceptable alignment and to have no distraction. Two or more of the risk factors for developing a nonunion (moderate or severe displacement or angulation, moderate or severe comminution, or a moderate or severe wound) had to have been present for inclusion Exclusion: Patient who had undergone surgical procedures other than those required for the initial management of a wound and open reduction (if necessary) of the initial fracture were excluded, treatment by internal or external fixation, gap greater than 0.5 cm, severe generalized disease, receiving systemic steroid treatment, bone disease (Paget’s), severely atrophic bone, and fractures with marked hypertrophy. Initial and prior treatments: patients with prior surgical procedures for treatment of the delayed union were excluded. The trial was limited to fractures of the tibial shaft that had received only conservative management. | Orthopaedic surgeon’s assessment - Active: 9 of 20 (45%) healed. Control: 3 of 25 (12%) healed. p = 0.02 based on Fisher’s exact test. Pain was reduced in both groups with no statistically significant differences between groups in any of the clinical criteria. | The authors report that an analysis using categorical modeling indicated that age was not a factor in the outcome of treatment. The authors had originally hoped for 100 patients, but after 6 years the multicenter trial could only enroll 51 patients and a decision was made to stop the trial. Since the fractures were evaluated after only 12 weeks of treatment, the healing rates may not be comparable to other studies. Follow-up data were provided by the sponsoring company (EBI) and are discussed in the text.(13,179) Clinical assessment did not match the radiological assessment. More than half of both groups did not show any movement of the fracture, a clinical sign that the fracture had healed. Movement indicates failure but lack of movement does not indicate a healed union.
Ito and Shirai 2001(116) | Retrospective Case Series Purpose: Assess the clinical efficacy of PEMF therapy in treating nonunion tibial fractures Level II-3 Internal validity criteria: low; 1. no (wide range of nonunion characteristics, retrospective data collection and analysis); 2. no (patients not listed as consecutive); 3. no (method of patient selection is not reported which allows for the possibility that results from dropouts were not reported); 4. no (assessment not masked); 5. yes; 6. no (pain and weight-bearing not reported); 7. no (no statistical analysis) | Device name not reported An electric current was generated in the bone by a pair of externally placed, oval, air-cored electromagnets. The tibia was immobilized with a long plaster cast. All patients were instructed to use the device for 8 hours each day and not to bear weight. Bones treated: tibia only Outcomes: Radiological signs of bone bridging. Patients were assessed every 6 weeks. Compliance not reported | n = 30 Mean age of 43 years with a range of 23 to 71 years Sex: F6 M24 Inclusion: delayed union or nonunion of the tibia according to the criteria of the American Orthopedic Group. Exclusion: none reported Initial and prior treatments: almost 80% had at least one surgical procedure, the average number of operations was 1.8 with 2 patients being operated on 5 times. 18 patients still had surgical hardware. Duration of disability was 6 months to 8 years with an average of 1.5 years. | 25 of 30 cases (83%) achieved bony union. Mean time to healing was 8.6 months with a range of 4 to 16 months. No statistical analysis was reported. Four of six patients with necrotic nonunions did not heal. | Three of the patients were 65 or over. 2 of the 3 patients healed. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Adams et al. 1992(126) | Retrospective Case Series Purpose: assess healing of scaphoid nonunions treated with PEMF. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. no (did not include dropouts in analysis); 3. yes; 4. no (assessment of healing not masked); 5. yes; 6. no (did not report pain or weight-bearing); 7. no (no statistical analysis | Device name not reported External PEMF coils were centered over the scaphoid and attached to either a long arm thumb spica cast or a short arm thumb spica cast. All patients were treated until the fracture healed or for at least a 3-month period. Bones treated: Scaphoid only Outcomes: Radiological signs of bone bridging and return to work. Followup: 1 to 33 months, mean of 8.5 months. Compliance not reported. | n = 54 Mean age of 26 years with a range of 14 to 46 years Sex: F3 M51 Inclusion: scaphoid nonunion fracture of at least 6 months duration and no operation had been performed during or just before initiation of PEMF treatment. Exclusion: displacement of significant angulation at the nonunions, arthritis of the periscaphoid joint, carpal instability. Initial and prior treatments: 10 patients had one previous bone-graft operation, 2 patients had previous operations. Average time from injury to treatment was 35 months, with a range of 6 to 241 months. | 37 of the 54 (69%) patients healed in a mean of 4 months with a range of 2.5 to 9 months. No statistical analysis was reported. 35 of the healed patients returned to their pre-injury work. | This study has limited relevance to the Medicare population because none of the patients were 65 years or over.
Garland et al. 1991(27) | Prospective Case Series Purpose: to prospectively evaluate the long-term safety and effectiveness of PEMF therapy for fracture nonunions and failed arthrodeses and to determine the effective treatment dosage ranges (hours/day) to achieve union, documented both clinically and radiographically. Level II-3 Internal validity criteria: fair; 1. yes; 2. yes; 3. no (28% dropout); 4. yes (blinding of assessment was not reported in the article but a personal communication from Orthofix indicated that the assessment was blinded)(7); 5. yes; 6. yes; 7. no (dropouts were not considered in calculating healing rate) | Device name was not reported in the publication. A personal communication from Orthofix indicated that the device used in this trial was the Physio-Stim Bone Growth Stimulator.(7) Patients were asked to use the PEMF device for a minimum of 6 months or until the nonunion healed. Immobilization, bracing and weight-bearing decisions were left to the judgment of the treating physician. A minimum of 12 weeks of treatment was considered necessary to complete treatment. Patients received treatment at 74 institutions. Bones treated: 15 femurs, 50 tibias, 8 fibulas, 7 humeri, 10 ulnae, 6 radii, 13 scaphoids, 10 ankles, 5 metatarsals, 11 other Outcomes: Radiological signs of bone bridging. Patients were determined to be clinically healed if they had no cast, no motion at the nonunion fracture site, and no or minimal pain at the nonunion site. Follow-up periods beyond the minimum 12 weeks of treatment were not reported. A subgroup was evaluated 4 years after treatment. Device usage was measured and a dose response relationship calculated. | n = 181 enrolled, 139 completed treatment Females n = 63: mean of 49 years with a range of 14 to 83. Males n = 118: mean of 38 years with a range of 13 to 73. Inclusion: nonunion fracture that failed to demonstrate both clinical and radiographic union at least 9 months after the original injury. Established nonunions that underwent a bone graft or internal fixation were candidates for PEMF treatment if evidence of healing was not apparent by 3 months after the procedure or if no progression of healing occurred during the 3-month period. Exclusion: none reported. Average duration of nonunion was 2.6 years (9 months to 42 years). Initial and prior treatments: prior surgical intervention has been performed on 81% of the fractures, fractures had an average of two previous surgeries, 113 internal fixation and bone grafting, 26 external fixation. | % healed: Long bones 83%, short bones 81%. Nonunion duration of less than 12 months 83%, 1 to 10 year duration 82%, 10 years or greater 44%. 87% femur, 74% tibia, 88% fibula, 100% humerus, 100% ulna, 83% radius, 77% scaphoid, 60% ankle, 80% metatarsal, and 73% other The average time to healing was not reported. Statistical analysis was based on confidence interval estimates. No statistically significant differences in success rates were observed among the usage strata above 3 hours per day. The success rate in the 13 patients averaging less than 3 hours daily use (36%) was significantly lower than that observed in the 126 patients averaging more than 3 hours (80%). In the 4-year subgroup, 92% of nonunions were healed. Chi-square analysis indicated no statistically significant difference between the 4-year healing rate and the original rate. | Union occurred in 90 of 107 (84%) patients less than 60 years of age and in 18 of 28 (64%) patients 60 years of age or older. No other information relative to age was reported.
Traina et al. 1991(14) | Retrospective Case Series with a comparison group Purpose: Attempt to quantify the effect of PEMF on healing of nonunion fractures Level II-3 Internal validity criteria: low; 1. no (retrospective data collection); 2. no (groups differed in mean age and types of bone treated); 3. yes; 4. no (not blinded); 5. yes; 6. yes; 7. yes | IGEA stimulator (Igea, Carpi, Italy) Patients were asked to use the PEMF device for 8 hours a day until they healed. A minimum of 12 months of treatment was considered necessary before the treatment could be considered a failure. The control group was treated simultaneously by the same group of surgeons. All patients maintained their current immobilization. Bones treated: Treated – 11 femur, 20 leg, 1 humerus, 8 forearm, 1 metatarsal, 0 clavicle; Control – 3 femur, 15 leg, 2 humerus, 3 forearm, 1 metatarsal, 2 clavicle Outcomes: Success was defined as radiological signs of bone bridging in at least 3 out of 4 cortices, no further surgery, and weight-bearing without pain or protection. The minimum follow-up was 2 years. | Treated group: n = 41, average age of 38 years, 5 F, 36 M, 18 infected. Control group: n = 26, average age of 46 years, 5 F, 21 M, 10 infected. Inclusion: nonunion fracture that failed to demonstrate both clinical and radiographic union at least 9 months after the original injury. Had not been operated on in the past 3 months. Immobilization had not been changed. Showed no signs of progression toward healing. Exclusion: none reported. Average duration of nonunion was 26 months (9 months to 180 months) in the control group and 21 months (9 months to 192 months). Initial and prior treatments: The average number of previous surgical interventions was 1.4 in the control group and 1.6 in the treated group. Three control patients and three treated patients had never been operated on. Control group: 9 plates, 6 medullary nails, 2 external fixation, 13 autogenous bone grafts; Treated group: 5 plates, 10 medullary nails, 7 external fixation, 17 casts, autogenous bone graft not reported for this group. | Treated group: 36 of 41 (88%) healed in an average of 5.7 months; 20 of 23 (87%) non-infected nonunions healed and 16 of 18 (88%) infected nonunions healed. Control group: 18 of 26 (69%) healed in an average of 7.8 months; 14 of 16 (87%) non-infected nonunions healed and 4 of 10 infected nonunions healed. Among non-infected nonunions, the healing rate was the same but the time to heal was significantly shorter in the treated group (t test, p <0.03). Among infected nonunions, the healing rate was significantly greater in the treated group (Fisher’s exact test, p <0.05) and the time to heal was significantly shorter in the treated group (t test, p < 0.04). Effects of PEMF stimulation are usually evident in the first 3 months of treatment. | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Comparison of healing rates between the treated and control groups is hindered by the differences in age and types of bone treated.
Meskens et al. 1990(117) | Retrospective Case Series Purpose: assess effect of PEMF in patients with a disability time of at least 24 months (interval between trauma and start of PEMF therapy), compare results with patients with shorter disability time, and evaluate prognostic factors. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. no (patients not listed as consecutive); 3. no (method of patient selection is not reported which allows for the possibility that results from dropouts were not reported); 4. no (assessment not masked); 5. yes; 6. yes; 7. no (no statistical analysis) | Device name not reported. All patients were strictly immobilized in a plaster cast with no weight-bearing. For the first 3 months, stimulation was 14 hours per day. For the next 3 months, stimulation was 10 hours per day. After 6 months, stimulation was only at night. Bones treated: 15 tibias, 9 femurs, 5 humeri, 2 ulnae, 2 radii, 1 fibula. Outcomes: Radiological signs of bone bridging and disappearance of gap, the disappearance of mobility on stress and of pain on percussion. Follow-up: mean of 5.7 years with a range of 24 months to 9 years. Compliance was not reported. | n = 34 Mean of 34 years with a range of 18 to 66 years. Sex: F11 M 23 Inclusion: Nonunion had to be at least 24-months old without any signs of progressing consolidation on x-rays taken at 2-month intervals. No operations for the nonunion in the 4 months preceding PEMF treatment. Exclusion: none reported. 8 hypertrophic, 5 atrophic, 21 neither type Initial and prior treatments: all patients had a period of unsuccessful plaster immobilization before beginning the PEMF therapy. On average, patients underwent 3 operations prior to PEMF therapy. 12 patients had prior bone graft. The mean disability time was 39 months with a range of 24 to 124 months. | 68% healed in a mean of 11.5 months with a range of 3 to 43 months. % healed: 73% tibia, 78% femur, 20% humerus 75% hypertrophic 0% atrophic 80% neither type Nonunions older than 9 months healed at 69%, 9 to 24 months at 71%, and greater than 24 months at 63%. No statistical analysis reported | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown.

Table D-4 Included Studies of Direct Current and Capacitive Coupling Treatment of Nonunion Fractures Addressing Key Question 6

Reference | Study Design / Purpose / USPSTF Study Quality Rating | Intervention / Outcomes | Demographics | Results | Comments
Brighton et al. 1995(16) | Retrospective Comparative study Purpose: Use logistic regression analysis to compare healing rates among 3 treatment methods, to identify risk factors adversely affecting the healing rate, and to predict the probability of successful healing of a nonunion of any given risk profile treated with each of the 3 therapies. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. yes; 4. no (assessment not masked); 5. yes; 6. no (did not report pain or weight-bearing); 7. yes | Device names not reported. Direct current (used from 1971 to 1982): 4 stainless steel cathodes inserted percutaneously into the nonunion site. Stimulation applied for 24 hours per day for 12 weeks. All patients wore a non-weight-bearing cast during the entire 12 weeks. Capacitive coupling (used from 1982 to 1994): stainless steel capacitor plates or electrodes placed on the skin through windows cut in the opposite sides of a newly applied cast. Stimulation applied continuously for 24 hours per day for 12 to 24 weeks. Bone graft (used throughout the study period): performed conventionally using autogenous iliac bone and accompanied by internal fixation in 15 patients, external fixation in 4 patients, and cast alone in 29 patients in whom rigid internal fixation was already in place. Type of treatment was determined by the preference of the individual study author treating the patient. Bones treated: Tibia only; 167 direct current, 56 capacitive coupling, and 48 bone graft. Outcomes: Radiological signs of bone bridging. | n = 271; direct current 167, capacitive coupling 56, bone graft 48. Mean age: direct current 35.9, capacitive coupling 35.9, and bone graft 33.3. No range reported. Sex: direct current F41 M126, capacitive coupling F12 M44, bone graft F16 M32. Inclusion: well-established nonunion of the tibia, defined as a fractured bone in which all radiographically demonstrable healing had ceased but bone continuity had been restored, no progressive signs of healing of the callus were seen during a 3-month period, and each nonunion had to be at least 9 months in duration. Exclusion: draining osteomyelitis of the nonunion was a cause for exclusion from treatment with direct current or bone graft surgery but not capacitive coupling. Prior treatments: Direct current group – 44 electric and 60 bone graft; Capacitive coupling group – 30 electric and 29 bone graft; and Bone graft group – 24 electric and 23 bone graft. | Results of logistic regression analysis: Best case: nonunion of 10 months duration prior to treatment with no risk factors: Direct current – 99% healed Capacitive – 96% healed Bone graft – 99% healed The analysis found no statistically significant differences in healing rates between the three treatments in this best case situation. As the duration of nonunion prior to treatment and the number of risk factors increased the probability of healing decreased. Worst case: nonunion of 70 months duration prior to treatment with 4 risk factors: Direct current – 39% healed Capacitive – 38% healed Bone graft – 10% healed The 4 risk factors are comminuted fracture, open fracture, prior use of electric stimulation, and prior use of bone graft. The analysis found no statistically significant difference in healing rates between the two electrical treatments in this worse case situation, but did find a statistically significant difference between bone graft and direct current (p = 0.01). Atrophic nonunions did not respond to capacitive coupling. Bone graft surgery was less effective in nonunions with previous bone graft failure. | Due to the lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Patient age was a continuous variable in the logistic regression analysis, but any influence age may or may not have on healing is not reported. Actual healing rates and time to healing are not reported, except for the patients treated with bone graft. 28 of 48 tibial nonunions treated with bone graft healed. No time to healing was reported. The logistic regression analysis indicates that duration of nonunion prior to treatment has a significant effect on the probability of healing. Without the actual results for each therapy at each follow-up period, we cannot verify that the results of the logistic analysis accurately represent the actual study results. The findings may not be generalizable beyond the patients in this study.
Zamora-Navas et al. 1995(17) | Retrospective Case series Purpose: Assess the healing of nonunion fractures with gaps wider than 1 cm when treated with electrical stimulation. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. yes; 4. no (assessment not masked); 5. yes; 6. no (did not report pain or weight-bearing); 7. no (no statistical analysis) | Device name not reported. All nonunions of the extremities were immobilized with either plaster cast, external fixation, or other procedures. All patients underwent capacitive coupling induced by an externally placed unit. The plates were attached to the skin overlying the nonunion site, placed on opposite sides of the patient’s limb. The unit was used all day. Bones treated: 10 tibias, 6 humeri, 2 radii, 1 femur, 1 ulna, 1 clavicle, 1 scaphoid. Outcomes: Radiological signs of bone bridging. Various treatment periods are reported with a range of 8 to 42 weeks. | n = 22 Mean age of 35 years with a range of 17 to 70 years Sex: F6 M16 Inclusion: well-established nonunion, demonstrated clinically by the presence of movement at the fracture site and radiologically by the presence of a fracture line. The fracture had to remain non-united for at least 9 months from the time of injury, and there had to be no radiologic changes for the last 3 months. Gap wider than 0.5 cm. Exclusion: none reported. Initial and prior treatments: 9 patients had prior operative treatment. No patients had prior electrical stimulation therapy. Average time between the original injury and electrical treatment was 63 weeks with a range of 30 to 216 weeks. | % healed: 80% tibia 67% humerus 100% radius 100% femur 100% ulna 0% clavicle 0% scaphoid Average period of treatment was 26 weeks with a range of 8 to 42 weeks. No statistical analysis is reported. | Two patients were 65 years of age or older. A 65 year old male showed a healed nonunion of the tibia after 42 weeks of treatment. A 70 year old female did not heal after 24 weeks of treatment. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Scott and King 1994(15) | Double-blinded, Randomized, Placebo-Controlled Trial Purpose: Determine the proper clinical role of electrical stimulation in the treatment of established nonunions by conducting an RCT. Level I Internal validity criteria: good; 1. yes; 2. yes; 3. yes; 4. yes; 5. yes; 6. yes; 7. yes | Orthopak bone-growth stimulator (Biolectron, Hackensack, New Jersey) capacitive coupling device was used. Bones treated: Active group – 5 tibias, 4 femurs, 1 ulna; Control – 10 tibias, 0 femur, 1 ulna Outcomes: Radiological signs of trabecular bone bridging on all 4 radiographs (anteroposterior, lateral, 2 oblique) no movement, and no pain. If no healing had taken place after 6 months, the patient was removed from the study and offered other treatment. | n = 21 of 23 completed study, 2 removed for noncompliance. Active (n = 10): mean age of 40 years with a range of 27 to 55; F 2, M 8 Control (n = 11): mean age of 46 years with a range of 23 to 87; F 3, M 8. Inclusion: Nonunion at least 9 months old, no clinical or radiographic signs of healing for at least 3 months, continuous immobilization from the time of the original injury with no other form of treatment, skeletal maturity. Exclusion: Operative or non-operative therapy in last 3 months, established Synovial pseudarthrosis, or a gap, or bone defect wider than one-half the width of the bone, generalized disorders of bone metabolism. Initial and prior treatments: Active - 3 patients had no prior bone surgery, 8 had internal or external fixation; Control – 1 patients had no prior bone surgery, 10 had internal or external fixation | 6 of the 10 (60%) actively treated patients healed in a mean of 21 weeks. None of the control patients healed after 26 weeks of treatment. Fisher exact test, p = 0.004, p = 0.02 if the two noncompliant patients are included. | The two patients older than 65 were included in the control group and did not heal. Therefore this study provided no evidence that older individuals will respond to ultrasound treatment. All 4 femur fractures were included in the Active group, which may have affected the results in favor of the active group. Analysis of the tibias only still showed statistical significance (p = 0.04)
Cundy and Paterson 1990(18) | Retrospective Case series Purpose: A 10-year review of a prior prospective nonrandomized study was carried out to evaluate the safety and effectiveness of an implanted bone growth stimulator. Specifically, the purpose was to answer whether there were any untoward safety effects, whether there were any refractures, or if healed fractures remained healed, and the long-term outcome of the treatment failures. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. no (44% of the original patients were not located); 3. no (44% of the original patients were not located); 4. no (assessment not masked); 5. yes; 6. no (did not report pain or weight-bearing); 7. no (no statistical analysis) | Device name not reported. The stimulator supplied a constant direct current that incorporated the anode and supplied the current via a single stainless steel or titanium cathode. Most patients received the titanium cathode helix. Stainless steel cathodes were removed but the titanium cathodes were allowed to remain and eventually become incorporated into the bone. The titanium cathode was left behind after the generator was removed. Bones treated: 33 tibias, 4 femurs, 1 other. Outcomes: Radiological signs of bone bridging. This article reports on 10-year followup. The average follow-up period was 10 years and 3 months with a range of 9 years and 6 months to 11 years and 11 months. | n = 37 29 patients were less than 30 years of age, 5 patients were between the ages of 30 and 49, and 3 patients were 50 years or older Sex: F4 M33 Inclusion: this article reports on the long-term followup of patients previously treated for delayed unions or nonunions with an implanted bone growth stimulator. The presence of an infection was not a contraindication. Exclusion: none reported. Initial and prior treatments: 17 patients had no prior surgery, 13 had one operation, 7 had two, and one had 3. Time between initial injury and implant was less than 9 months in 25 patients, between 9 and 17 months in 5 patients, and 18 or more months in 8 patients. | In the original study, 72 of 84 (86%) nonunion fractures showed radiographic signs of bone bridging. All 38 fractures in the 37 patients in this followup were healed. Six of these patients had not healed in the prior study but were now healed through the use of bone grafting and internal fixation. | Due to the lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Only three patients in this study were over the age of 50. Some ankles and knees were stiff due to prolonged immobilization. In some patients the remaining cathode was incorporated into the bone, but the patients had no clinical or radiographic signs of an adverse reaction to the cathode.

Table D-5 Included Studies of Shock wave Treatment of Nonunion Fractures Addressing Key Question 6

Reference | Study Design / Purpose / USPSTF Study Quality Rating | Intervention / Outcomes | Demographics | Results | Comments
Biedermann et al. 2003(19) | Prospective Case series Purpose: To determine the value of extracorporeal shock waves for the treatment of nonunions, analyzing previous published studies and our own clinical results. Level II-3 Internal validity criteria: low; 1. yes; 2. yes; 3. yes; 4. no (radiographic assessment was not masked); 5. yes; 6. no (pain and weight-bearing were not reported); 7. no (no statistical analysis) | MFL 5000 Lithotriptor shock wave device was used in this study. All patients were treated once, 12 patients were treated twice. Bones were immobilized with plaster or braces for 6 weeks to 3 months. Bones treated: 58 long bones, 12 other; 34 hypertrophic nonunions, 12 hypertrophic delayed unions; 22 atrophic nonunions, 2 atrophic delayed unions. Outcomes: Radiographic evidence of bone bridging. Followup of 6 weeks, 3 months, and later for persistent nonunions. | n = 73 Mean of 42 years Sex: F34 M39 Inclusion: delayed or nonunion (failed bone healing of more than 6 months) fracture. Exclusions: bone tumors, pathologic fractures, recent infections, dysfunction of coagulation, nonunions close to the epiphyseal growth plate, pregnancy, nonunions of the thoracic bones, nonunions close to the central nervous system, open fractures. Initial and prior treatments: did not report prior treatments. Duration of nonunion before shock wave therapy averaged 19 months with a range of 6 to 74 months. Duration of delayed unions before shock wave therapy averaged 5 months with a range of 0.2 to 5 months. | % of patients with bony union: 25 of 45 (55%) long bone nonunions; 12 of 13 (92%) of long bone delayed unions; 7 of 11 (63%) other nonunions; 1 of 1 (100%) other delayed unions. 21 of 34 (62%) hypertrophic nonunions, 11 of 12 (92%) hypertrophic delayed unions. Mean time to heal was 5.3 months for nonunions. 11 of 22 (50%) atrophic nonunions, 0 of 2 (0%) atrophic delayed unions. Mean time to heal was 3.4 months. A statistical analysis was not reported. No major adverse events; some transient tissue swelling and subcutaneous bleeding. | Due to limited reporting of patient characteristics, the relevance of this study to the Medicare population is unknown. Among pertinent patient characteristics, only the mean age was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Rompe et al. 2001(20) | Prospective Case series Purpose: Examine the effects of shock wave therapy on nonunion fractures of the femur and tibia. Level II-3 Internal validity criteria: fair; 1. yes; 2. yes; 3. yes; 4. yes (used blinded assessment); 5. yes; 6. no (did not consider pain); 7. no (no statistical analysis) | Siemens Osteostar shock wave device was used in this study. All patients were treated once. The limbs remained in casts with limited weight-bearing. Bones treated: 19 tibial nonunion, 24 femoral nonunion. Outcomes: Radiographic evidence of bone bridging and weight-bearing. Followup period of 8 weeks and then monthly for 9 months. | n = 43 Mean of 39.5 years and range of 18 to 74 Sex: F20 M23 Inclusion: Skeletally mature men and women with bony nonunion of the long bones of the lower extremity. Minimum of 9 months had elapsed since the last operation and no radiologic bridging was observed. Exclusion: loosening of screws and plates, bone gap more than 0.5 cm, local infection, pathologic fracture, pregnancy, patient receiving steroids, anticoagulants, nonsteroidal anti-inflammatory medication, diphosphonate therapy, calcium channel blockers, or immunosuppressive therapy, patients with a history of thrombophlebitis or vascular insufficiency, drug addiction, hepatitis, and human immunodeficiency virus infection. 18 patients were smokers. Initial and prior treatments: patients averaged 2 unsuccessful operations with a range of 1 to 6. | 31 of 43 (72%) patients showed bony bridging and could bear full weight by an average of 4 months. 13 of 19 (68%) tibias healed; 18 of 24 (75%) femurs healed. 19 of 24 (79%) nonsmokers healed; 12 of 19 (63%) smokers healed. No statistical analysis was reported. No major adverse events; some transient subcutaneous bleeding. | Four of the patients were older than 65 years (65, 70, 73, and 79). 3 of the 4 healed in an average of 4 months. The 73 year old patient did not heal. Provided individual patient data but did not report comorbidities other than smoking.
Schaden et al. 2001(21) | Retrospective Case series Purpose: Describe the early results in the application of high-energy shock waves using a device specifically designed for orthopedic use in the treatment of delayed unions and nonunions. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. yes; 4. no (did not mask assessment); 5. yes; 6. no (did not consider pain and weight-bearing); 7. yes | Device name not reported. All patients received one shock wave treatment. After treatment the fractures were immobilized with casts or splints unless implanted devices showed no signs of loosening. 60 patients still had internal fixation devices. Bones treated: Multiple types including 34 tibias, 21 scaphoids, and 12 femurs; 35 delayed and 80 nonunions. Outcomes: Radiographic evidence of bone bridging. Followup of 4, 8, and 12 weeks plus a total followup of 3 months to 4 years. | n = 115 Females: mean of 47 years, range of 15 to 85 Males: mean of 41 years, range of 10 to 86 Sex: F41 M 74 Inclusion: nonunions (more than 6 months) or delayed (3 to 6 months) fracture healing. Exclusion: coagulopathy, acute infection, pregnancy, any of the following within the shock wave field: epiphyseal plate, malignant tumor, alveolar tissue, brain, or spine. Initial and prior treatments: 23 patients had initial conservative treatment, 92 had operative treatment. 28 patients were operated on twice and 25 were operated on 3 or more times. | 26 of 35 (74%) delayed unions healed and 61 of 80 (76%) nonunions healed. 26 of 34 (76%) tibias, 14 of 21(67%) scaphoids, and 11 of 12 (92%) femurs healed. There was no significant difference among the success rates of the groups of patients with delayed nonunions, nonunions, or previously infected nonunions (statistical methods were not reported). No major adverse events; some transient tissue swelling and subcutaneous bleeding. | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. The authors state that positive results and treatment failures were not correlated with the age of the patients. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Wang et al. 2001(119) | Prospective Case series Purpose: Review the clinical results in the treatment of patients with nonunion fractures of long bones treated with shock waves. Level II-3 Internal validity criteria: fair; 1. yes; 2. yes; 3. yes; 4. no (assessment not masked); 5. yes; 6. yes; 7. yes | The OssaTron Shockwave device was used in this study. Patients received one shock wave treatment with one additional treatment after 3 months if nonunion persisted. Patients were allowed mobilization with crutches, partial weight-bearing for fractures of lower extremity, and sling for upper extremity. Bones treated: 41 femurs, 19 tibias, 7 humeri, and 5 other long bones. Outcomes: Radiographic evidence of bone bridging, pain measured by 0 to 10 visual analog scale, percentage of weight-bearing, and functional use of affected limb. Follow-up periods of 6 weeks, 3, 6, 9, and 12 months. | n = 72 Mean of 39 years and range of 15 to 74 years Sex: F19 M 53 Inclusion: established nonunions of long bone fractures defined as a failure to show bone union 6 months after initial closed or open treatment. All patients must be skeletally mature. Exclusion: underlying neoplastic disease or other causes of pathologic fracture, fractures in the epiphyseal region of the bone, a fracture gap greater than 0.5 cm, active infection, fractures in younger patients in whom the epiphyseal plate has not closed, pregnancy, cardiac pacemakers, use of immunosuppressive drugs or anticoagulants, and fractures near major neurovascular structures in the spine, chest, and skull. Presence of orthopedic implants was not a contraindication. Initial and prior treatments: 8 patients were treated initially with a closed reduction and cast immobilization. The remaining 64 had undergone at least one open reduction and internal fixation; 41 with femur fractures, 33 initially were treated with an intramedullary nail, 7 with plate fixation, and 1 with nail and plate. The average number of operations prior to shock wave therapy was 1.3 with a range of 1 to 6. 23 patients had received bone graft on 1 to 3 occasions. | 9 patients were lost to followup and 8 patients chose surgical intervention. 3 months, 70 patients: Pain declined from 2.65 to 1.11 (p <0.001); weight-bearing increased from 60% to 74% (p <0.001); bony union in 50% of hypertrophic nonunions (19 of 38), 47% of nonunions with a defect (9 of 19), and 0% of atrophic nonunions (0 of 13). 6 months, 61 patients: Pain declined from 2.5 to 0.4 (p <0.001); weight-bearing increased from 60% to 82% (p <0.001); functional use improved from 50% to 74% (p <0.001); bony union in 68% of hypertrophic nonunions (23 of 34), 69% of nonunions with a defect (11 of 16), and 27% of atrophic nonunions (3 of 11). 12 months, 55 patients: Pain declined from 2.6 to 0.1 (p <0.001); weight-bearing increased from 60% to 91% (p <0.001); functional use improved from 47% to 80% (p <0.001); bony union in 81% of hypertrophic nonunions (25 of 31), 81% of nonunions with a defect (13 of 16), and 75% of atrophic nonunions (6 of 8). Statistical methods were not reported. No major adverse events; some transient subcutaneous bleeding. | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Report contains information on pain, weight-bearing and limb function for up to 12 months after treatment, but did not differentiate between patients in different age groups.
Vogel et al. 1997(120) | Prospective Case series Purpose: To evaluate the success rate of shock wave therapy in treating nonunions of the lower extremity. Level II-3 Internal validity criteria: low; 1. yes; 2. yes; 3. yes; 4. no (did not mask assessment); 5. yes; 6. no (did not consider pain and weight-bearing); 7. no (no statistical analysis) | The Siemens OsteoStar was used in this study. All patients were treated once. After treatment predominantly involved applying a cast. Bones treated: 17 femurs, 19 tibias, 9 metatarsals, and 3 other bones. Outcomes: Radiographic evidence of bone bridging. Followup at 3, 6, 12, 18, 24 and 52 weeks. | n = 48 Mean of 38 years and range of 12 to 81 years Sex: F23 M25 Inclusion: nonunions of the leg with a history of more than 6 months. Exclusion: acute osteomyelitis, defects close to growth plate, pathological fractures, coagulation disorders, pregnancy, and malignancy. Initial and prior treatments: Patients average 2.4 operations prior to treatment. The mean duration of nonunion prior to treatment was 12 months with a range of 6 to 48 months. | At a mean of 3.4 months (range of 2 to 9 months) 29 of 48 (60%) patients showed complete healing. Healing rates for individual bone types were not reported. No statistical analysis was reported. No major adverse events; some transient tissue swelling and subcutaneous bleeding. | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Only radiographic evidence of bone bridging was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.
Valchanou and Michailov 1991(22) | Retrospective Case series Purpose: Present the results of the application of extracorporeal high-energy shock wave in the treatment of delayed unions and nonunions. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. no (patients not reported as consecutive); 3. no (loss to followup not reported); 4. no (did not mask assessment); 5. yes; 6. no (did not consider pain and weight-bearing); 7. no (no statistical analysis) | The device name was not reported. Patients were each treated once. Most fractures were immobilized in a plaster cast. Bones treated: 6 femurs, 10 tibias, 1 patella, 1 fibula, 5 humeri, 11 ulnae, 21 radii, 17 scaphoids, 7 phalanges. Outcomes: Radiographic evidence of bone bridging. No follow-up periods were reported. | n = 79 Mean age of 28 years and range of 9 to 76 years Sex: F8 M71 Inclusion: delayed or nonunion fractures. Exclusion: none reported. Initial and prior treatments: 52 patients had had 1 to 5 previous operations. The average time after injury until shock wave treatment was 20 months. | 70 of 79 (85%) patients showed radiographic evidence of bone bridging. Average time until healed was not reported. Femur: 5 of 6, 83% Tibia: 7 of 10, 70% Scaphoid: 13 of 17, 76% Radius: 19 of 21, 90% Ulna: 10 of 11, 91% Phalanges: 7 of 7, 100% Humerus: 5 of 5, 100% Patella: 0 of 1, 0% Fibula: 1 of 1, 100% No statistical analysis was reported. No “troublesome” side effects were reported. | Due to the wide range of ages and lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. Only radiographic evidence of bone bridging was reported, but no time period for healing was reported. Other outcome measures such as pain, weight-bearing, and return to normal activities were not reported.

Table D-6 Included Studies of Orthobiologics Treatment of Nonunion Fractures Addressing Key Question 6

Reference | Study Design / Purpose / USPSTF Study Quality Rating | Intervention / Outcomes | Demographics | Results | Comments
Friedlaender et al. 2001(23) | Prospective randomized controlled trial Purpose: Establish the safety and efficacy of OP-1 in treating nonunions of the tibia and determine if OP-1 is comparable to bone graft for the treatment of tibial nonunions. Level I Internal validity criteria: fair; 1. yes; 2. yes; 3. yes; 4. no (treatment could not be blinded, but radiographic assessment was blinded); 5. yes; 6. yes; 7. yes | All patients underwent intramedullary rod fixation. Osteogenic protein-1 (OP-1, also BMP-7, from Stryker Biotech) implant: patients received one or two units of recombinant human osteogenic protein-1 (rhOP-1) implanted in the fracture site. Each unit consisted of 3.5 mg of rhOP-1 and 1 gram of bovine bone-derived collagen. Bone autograft: the procedure is not described. Bones treated: tibia only. Outcomes: Radiological signs of bone bridging judged by three radiologists blinded to the treatment. Clinical assessment included the presence of pain at the fracture site upon weight-bearing, the ability to bear weight, and the need for further surgical intervention for the purpose of enhancing fracture repair (re-treatment). Combined clinical criteria for success was full weight-bearing, less than severe pain at the fracture site on weight-bearing, and no re-treatment. Patients were examined at 1, 2, 3, 6, 9, 12 , and 24 months after treatment. The primary end-point was 9 months. | n = 63 implant and 61 autograft OP-1 implant: mean of 38 years with a standard deviation of 16. Bone autograft: mean of 34 years with a standard deviation of 11. Sex: OP-1: F20 M41; Autograft: F14 M47 Inclusion: tibial nonunions requiring 9 months duration of the non-united fracture with no evidence of progressive healing over the previous 3 months. Exclusion: patients who, in the judgment of their treating orthopedic surgeon, were candidates for internal fixation alone, clinically apparent infection in the fracture site, skeletally immature, severely compromised soft-tissue coverage, pathological cause for the fracture, receiving radiation, chemotherapy, immunosuppression, or chronic steroids, are or could become pregnant, breastfeeding, congenital or synovial pseudarthrosis of the tibia, neuropathy that would interfere with walking or appreciating pain, nonunions of multiple bones other than the tibia, autoimmune disease, sensitivity to collagen. Smoking: 74% of OP-1, 57% of bone autograft. Initial and prior treatments: Prior autograft: 43% OP-1 and 31% bone graft. Prior IM rod: 54% OP-1 and 44% bone graft. There were no statistically significant differences in the distribution of prior autografts or bone grafts. Atrophic nonunions were significantly more prevalent in the OP-1 group, 41% vs. 25%, p = 0.048. Median duration of nonunion prior to treatment was 17 months in both groups. Tobacco/nicotine use was 74% in the OP-1 group and 57% in the autograft group but was not significant (p = 0.06). | At 9 months:; [underlined: % Adverse events associated with the bone graft donor site (only BG group)] All patients reported post-operative pain, 80% judged the pain to be moderate or severe. At 6 months 20% of patients reported persistent pain (mild to moderate) and at 12 months 13% had persistent pain at the donor site. | Due to the lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. The influence of patient age on nonunion healing was not part of the reported data analysis. Patients and physicians could not be blinded to treatment because of the presence of a bone graft donor site in patients who received bone graft. The proper statistical comparison for this study is a non-inferiority analysis. See the text for a discussion of this approach to demonstrating that one treatment is not inferior to another treatment.
  % Success | OP-1 | BG | p-value
  Weight-bearing | 86% | 85% | NS
  Pain on weight-bearing | 89% | 90% | NS
  Combined | 81% | 85% | NS
  Bridging (1 view) | 75% | 84% | NS
  Bridging (3 views) | 62% | 74% | NS
  No retreatment | 95% | 90% | NS
  Physician satisfaction | 86% | 90% | NS
  % Adverse events | OP-1 | BG | p-value
  Arthralgia | 13% | 8% | NS
  (neuralgic pain in a joint or joints)
  Pain, multiple sites | 13% | 15% | NS
  Osteomyelitis | 3% | 21% | 0.002
  Fever | 51% | 46% | NS
  Vomiting | 30% | 31% | NS
  Leg edema | 8% | 11% | NS
  Postoperative infection | 23% | 20% | NS
Wilkins and Kelly 2003(24) | Retrospective Case series Purpose: Assess the effectiveness of a commercially prepared allograft demineralized bone matrix in patients with long bone gaps and nonunions. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. no (loss to followup was not reported); 4. no (assessment was not masked); 5. yes; 6. yes; 7. yes | AlloMatrix Injectable Putty (Wright Medical Technology), a combination of demineralized bone matrix (AlloSource) and surgical-grade calcium sulfate carrier (OsteoSet) was used in this study. Nonunions were treated using standard internal/external fixation techniques. The periosteum surrounding the nonunion site was elevated to create an area into which the putty was placed. The periosteum was then closed around the site. Bones treated: 13 tibias, 10 humeri, 6 ulnae, 5 femurs, 1 fibula Outcomes: Bone Healing Index Patients were judged as healed when the numerical total of the radiographic score (1: no bone bridging to 5: cortical bridging) and clinical score (1: pain with rest to 5: normal function) was 8 or more. Average followup was 6 months. | n = 35 nonunions and 41 being treated for bone voids. Mean of 45 years with a range of 18 to 76 years for the nonunion group. Sex: F40 M36 (value for entire study group including patients being treated for bone voids) Inclusion: a surgeon recommended cancellous (spongy) bone graft as treatment, the void shape could accommodate graft material, and patients were willing to release medical data and return for postoperative followup. Exclusion: none reported. Initial and prior treatments: Not reported. | Average time to healing was 3.5 months. 30 of 35 (85.7%) patients were healed according to radiographic evidence. Healing rates were not reported separately for individual bone types. Re-fracture after successful healing: 2 Hardware failure: 1 Postoperative neuromas over the scar: 1 Decreased range of motion due to adhesions: 1 Recurrent infection: 1 | Due to the lack of outcome reporting by age groups, the relevance of this study to the Medicare population is unknown. The influence of patient age on nonunion healing was not part of the reported data analysis. Whether the authors actually used the Bone Healing Index to judge the healing process is not clear. Therefore, the extent to which normal function was achieved cannot be determined.
Johnson and Urist 2000(127) | Retrospective Case series Purpose: Assess the effectiveness of a composite inductive allograft in healing femoral nonunions. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. yes; 4. no (assessment was not masked); 5. yes; 6. no (did not consider pain or weight-bearing); 7. no (no statistical analysis) | A composite allograft consisting of an allogeneic, autolyzed, antigen-free cortical bone carrier with partially purified human bone morphogenetic protein, abbreviated as hBMP/AAA, was used in this study. The allograft contained 100 mg of partially purified hBMP lyophilized into the implant. 13 patients received additional autogenic cancellous bone graft to the intercalary segmental defect. 26 patients were implanted with a fixed angle blade plate to stabilize and lengthen the femur. The procedure involved bone lengthening. The remaining patients had intramedullary nails. Bones treated: all femurs. Outcomes: Radiological signs of bone bridging. Follow-ups averaged 58 months with a range of 11 to 153 months. | n = 30 Mean age of 47 years with a range of 28 to 75 years. Sex: F20 M10 Inclusion: patients with femoral diaphyseal or diaphyseal-metaphyseal reconstructions augmented with hBMP/AAA. Exclusion: none reported. Initial and prior treatments: 16 patients had 34 failed IM nailings, 17 had 25 failed diaphyseal or metaphyseal platings, 8 patients had failed IM nailing and plating. There was an average of 2 previous failed procedures per patient with a range of 1 to 4 procedures and an average of 2 failed autogenous cancellous bone grafts per patients with a range of 1 to 4 graftings. The average duration of nonunion was 39 months with a range of 9 to 60 months. | 24 of 30 (80%) femoral nonunions showed healing with an average time of 6 months and a range of 3 to 9 months. No statistical analysis was reported. 6 patients had a fatigue failure of the implant. There were no infections, wound healing problems, neurovascular compromises, or significant loss of knee motion after lengthening. | 8 of the patients were 65 years of age or older. 7 of these 8 patients showed healing within 4 to 6 months. The partially purified hBMP used in this study was prepared by the authors.
Johnson et al. 1992(128) | Retrospective Case series Purpose: To investigate repair of unhealed fractures and bone defects under the influence of bone morphogenetic protein (BMP) implanted using cortical bone as a delivery system. Level II-3 Internal validity criteria: low; 1. no (retrospective data collection and analysis); 2. yes; 3. yes; 4. no (assessment was not masked); 5. yes; 6. no (did not consider pain or weight-bearing); 7. no (no statistical analysis) | A composite allograft consisting of an allogeneic, autolyzed, antigen-free cortical bone carrier with partially purified human bone morphogenetic protein, abbreviated as hBMP/AAA, was used in this study. The hBMP/AAA implant was surgically placed in the defect. 22 patients were also treated with adjunctive internal fixation and 7 patients received adjunctive bone grafting. Bones treated: 7 tibia, 12 femur, 6 humerus. Outcomes: Patients were evaluated on 3 categories: anatomic (extent of radiological signs of bone healing), economic (ability to return to work), and functional (ability to perform activities of daily living). Each category was scored from 0 (worst outcome) to 4 (best outcome). Followup averaged 20 months with a range of 5 to 82 months. | n = 25 Mean of 45 years with a range of 13 to 75 years. Sex: F16 M9 Inclusion: resistant nonunions including partial or complete segmental defects treated with hBMP/AAA. Initial and prior treatments: 22 patients had long-term failure of PEMF therapy, 23 had previous failed surgical procedures with an average of 3 and a range of 1 to 8. Duration of nonunions averaged 30 months with a range of 5 to 83 months. | 20 of 25 (80%) nonunions united after the first implantation of the composite graft. 4 of the 5 failures healed after revision of the failed fixation. Average healing time was 6 months with a range of 3 to 14 months. 14 patients finished with scores of 4 in the 3 evaluation categories. 5 patients had scores of 3 in all 3 categories. 15 of the 19 patients with tibia or femur nonunions were able to walk without support. All 12 femurs healed, 6 of 7 (86%) tibias healed, all 6 humeri healed. No statistical analysis was reported. There were no complications related to infection, rejection, or evidence of delayed immune response attributable to the hBMP/AAA implant. | 5 patients were 65 years or older. 3 had nonunions of the tibia. All healed and were able to perform activities of daily living. 2 had nonunions of the humerus. All healed and were ability to perform activities of daily living. The partially purified hBMP used in this study was prepared by the authors.