# Evidence Tables for Key Question 4

Table C-1 Intermediate and Patient-Reported Outcomes of Treatment for Nonunion Fractures

Outcome | Definition of successful treatment | References
Radiographic evidence of bone bridging | Three of four cortices had to be bridged in long bones | (9–11,23)
Radiographic evidence of bone bridging | All four radiographic views showed bony trabeculae spanning the full width of the nonunion gap | (16,20,119)
Radiographic evidence of bone bridging | Two planes showing bony trabecular crossing at least half of the width of the defect | (116)
Radiographic evidence of bone bridging | The fracture line was bridged with callus bone in non-long bones; loss of fracture line | (9,11,119)
Radiographic evidence of bone bridging | Trabecular bridging of at least 80% of the fracture in the case of cancellous fractures such as scaphoid fractures | (10,11)
Pain at site of nonunion | Absence of pain | (9)
Pain at site of nonunion | No more than slight tenderness | (116)
Pain on weight-bearing | No pain on weight-bearing | (9)
Pain on weight-bearing | Less than severe pain at the fracture site on weight-bearing | (23)
Bone healing index | Patients were judged as healed when the numerical total of the radiographic score (1: no bone bridging to 5: cortical bridging) and clinical score (1: pain with rest to 5: normal function) was 8 or more | (24)
Limb function | Return of normal limb function | (9,119)
Limb function | Full weight-bearing | (23)
Retreatment | No retreatment | (23)