# Orthobiologics and Bone Growth Stimulating Devices Used to Treat Nonunion Fractures

Table B-1 List of Orthobiologics Used to Treat Nonunion Fractures

Specific Product Name | Company Name | US Food and Drug Administration Status | References
OP-1 Implant – recombinant osteogenic protein 1 (or BMP-7) and bovine bone collagen In Europe this product is called Osigraft | Stryker Biotech | In October 2001, the FDA granted Stryker Biotech a humanitarian device exemption (HDE) for the use of OP-1 Implant for use as an alternative to autograft in recalcitrant long bone nonunions where use of autograft is unfeasible and alternative treatments have failed. | (154) (23)
Infuse Bone Graft – contains recombinant human Bone Morphogenetic Protein-2 in an Absorbable Collagen Sponge (rhBMP-2/ACS) InductOS in Europe | Wyeth Pharmaceuticals | Has premarket approval (PMA in 2004) for use in the treatment of acute, open tibial shaft fractures in adults. To be used with internal fixation (intramedullary nail) | (155)
Palacos E-Flow (Osteopal) Bone Cement | Biomet Merck | Has premarket approval (PMA in 1998) for changes in the bone cement composition. The device, as modified, will be marketed under the trade name Osteopal (E-Flow) and is indicated for use as a bone cement in arthroplastic procedures of the hip, knee, and other joints to fix plastic and metal prosthetic parts to living bone when reconstruction is necessary because of osteoarthritis, nonunion of fractures of the neck of the femur, sickle cell anemia, osteoporosis, secondary severe joint destruction following trauma or other conditions (also for fixation of unstable fractures in metastatic malignancies), and revision of previous arthroplasty procedures. Also has 510k clearance as a polymethylmethacrylate bone cement.
AastromReplicell System – proprietary culture process for the ex vivo production of bone marrow cells, combined with a beta tri-calcium phosphate (Calcibon Granules, Biomet Merck) | Aastrom Biosciences, Inc (Ann Arbor, Michigan) | No approvals. Currently in phase I/II clinical trials in the U.S. | (156) (157)
OsteoSet – calcium sulfate (Plaster of Paris) OsteoSet –T, osteoset with tobramycin antibiotic | Wright Medical Technology | Received 510k clearance in 1996 as a resorbable calcium salt bone void filler | (158) (159)
OsteoSet BVK kit – contains a sterile pre-measured surgical grade calcium sulfate, mixing solution, tools to mix | Wright Medical Technology | Received 510k clearance in 2001. Resultant paste is to be injected, digitally packed into open bone void/gap that are not intrinsic to the stability of bone structure of the skeletal system (extremities, spine, and pelvis). The open bone voids may be surgically created osseous defects or osseous defects created from traumatic injury to the bone.
OsteoSet DBM pellets – surgical grade calcium sulfate incorporating human demineralized bone matrix (DBM) | Wright Medical Technology | Received 510k clearance in 2004. OsteoSet DBM pellets are indicated only for bony voids or gaps that are not intrinsic to the stability of bony structure. OsteoSet DBM pellets are intended to be gently packed into bony void or gaps of the skeletal system (extremities, spine, and pelvis). These defects may be surgically created osseous defects or osseous defects created from traumatic injury to the bone. | Company Web sites mentions its use for nonunions
AlloMatrix Putty – contains demineralized bone matrix (Allogro from AlloSource), carboxymethylcellulose, and OsteoSet | Wright Medical Technology | Received 510k clearance in 2004. AlloMatrix is indicated only for bony voids or gaps that are not intrinsic to the stability of bony structure. AlloMatrix is intended to be gently packed into bony void or gaps of the skeletal system (extremities, spine, and pelvis). These defects may be surgically created osseous defects or osseous defects created from traumatic injury to the bone. A variety of other AlloMatrix products were also given 510k clearance in 2004 with the same indications. | (159) (106) Company Web site mentions its use for nonunions
Allogran-R – beta tri-calcium phosphate synthetic bone substitute | Biocomposites (England) | Allogran-R has not been cleared by the FDA for any purpose. | Company Web site mentions its use for nonunions
Norian SRS Bone Void Filler – carbonated hydroxyapatite | Synthes (USA) | Received 510k clearance in 2001. Norian SRS is indicated only for bony voids or gaps that are not intrinsic to the stability of bony structure. Norian SRS is intended to be gently packed into bony void or gaps of the skeletal system (extremities, spine, and pelvis). These defects may be surgically created osseous defects or osseous defects created from traumatic injury to the bone. | (160)
JAX CS bone graft substitute | Smith and Nephew | JAX is indicated only for bony voids or gaps that are not intrinsic to the stability of the bony structure. JAX™ is indicated to be gently packed into bony voids or gaps of the skeletal system, (i.e., the extremities, spine, and pelvis). These defects may be surgically created osseous defects or osseous defects created from traumatic injury to the bone. JAX™ provides a filler that is resorbed and is replaced with bone during the healing process. Because JAX™ is biodegradable and biocompatible, it may be used at an infected site. | Company Web site mentions its use as a bone graft substitute and that bone grafts are used for nonunions (8)

Table B-2 List of External Bone Growth Stimulating Devices Used to Treat Nonunion Fractures

Specific Device Name | Company Name | US Food and Drug Administration Status | References
Ultrasound Systems
Sonic Accelerated Fracture Healing System Model 2A Original PMA number P900009 | Smith & Nephew, Inc. Memphis, TN 38116 | Received PMA in 1994 as a bone growth stimulator
Sonic Accelerated Fracture Healing System Model 2000 Supplement to PMA number P900009 | Exogen, Inc. Piscataway, NJ 08855 | Received PMA in 2000 for the non-invasive treatment of established nonunions excluding skull and vertebrae, and for accelerating the time to a healed fracture for fresh, closed, posteriorly displaced distal radius fractures, and fresh, closed or Grade I open tibial diaphysis fractures in skeletally mature individuals when these fractures are orthopedically managed by closed reduction and cast immobilization. A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing | (161) (162) (163)
Exogen 3000® Sonic Accelerated Fracture Healing System Supplement to PMA number P900009 | Exogen, Inc., Piscataway, NJ 08855 | Received PMA in 2000 for various design and manufacturing changes which do not affect the output of the device. The device, as modified, will be marketed under the trade name Exogen 3000
Exogen 2000 Sonic Accelerated Fracture Healing System (SAFHS®) Supplement to PMA number P900009 | Smith & Nephew, Inc. Memphis, TN 38116 | Received PMA in 2001 for the low intensity ultrasound fracture treatment system, Sonic Accelerated Fracture Healing System (SAFHS®). The device, as modified, will be marketed under the trade name Exogen 2000 Sonic Accelerated Fracture Healing System (SAFHS®) and is indicated for the non-invasive treatment of established nonunions* excluding skull and vertebrae. In addition, the Exogen 2000+™ or Sonic Accelerated Fracture Healing System (SAFHS®) is indicated for accelerating the time to a healed fracture for fresh, closed, posteriorly displaced distal radius fractures and fresh, closed or Grade 1 open tibial diaphysis in skeletally mature individuals when these fractures are orthopedically managed by closed reduction and cast immobilization. *A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing. | (9) (10) (164) (165)
Exogen 3000® Sonic Accelerated Fracture Healing System Supplement to PMA number P900009 | Exogen, Inc., Piscataway, NJ 08855 | Received PMA in 2001 for a change in labeling for the Exogen 3000®, to incorporate both the fresh fracture and nonunion information into one set of Physician’s Instructions for Use, Patient’s Instructions for Use, and Product Insert Bulletin; to make manual size and formatting changes, and to add nonunion background information.
Pulsed electromagnetic field systems
Bio Osteogen System 204 Original PMA number P790002 | Electro-Biology, Inc. | Received PMA in 1979
EBI Bone Healing System® FLX® Coilette Supplement to PMA number P790002 | Electro-Biology, Inc. | Received PMA in 1997 for the FLX® Coilette which will be used to deliver the approved repetitive pulse burst signal produced by the EBI Bone Healing System Model 1200. To be used with the EBI Bone Healing System Model 1200 which is indicated for nonunions, failed fusions, and congenital pseudarthroses
EBI Bone Healing System Model 2001 Supplement to PMA number P790002 | Electro-Biology, Inc. | Received PMA in 1999 for “the treatment of fracture nonunions, failed fusions, and congenital pseudoarthroses in the appendicular system.”
EBI Bi-Osteogen™/Bone Healing System® FLX®-S Coils (FLX 2-S, FLX 3-S, and FLX 4-S) Supplement to PMA number P790002 | Electro-Biology, Inc. A Subsidiary of Biomet, Inc. Parsippany, NJ 07054-1079 | Received PMA in 1998 for the FLX®-S Coils (model numbers FLX 2-S, FLX 3-S, and FLX 4-S) which will be used to deliver the single repetitive pulse (SRP) signal produced by the EBI Bone Healing System® Model 1020-S control unit. The device, as modified, will be marketed under the trade name EBI FLX®-S Coils and used with the EBI Bone Healing System® Model 1020-S control unit which is indicated for the treatment of nonunions, failed fusions, and congenital pseudarthroses.
EBI Bone Healing System Supplement to PMA number P790002 | Electro-Biology, Inc. Parsippany, NJ, 07054-1079 | Received PMA in 1998 for revision of the indications and usage section of the labeling for Models 1200, 1020-S, 1026, and 101, to include the definition of nonunion recommended by the Orthopedic and Rehabilitation Devices Panel on April 28, 1998 and required per FDA’s letter dated June 3, 1998 (i.e., “nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing”).
Orthologic 1000 bone Growth Stimulator Original PMA number P910066 | DJ Orthopedics, LLC/Regentek | Received PMA in 1994 as a bone growth stimulator
OrthoLogic® 1000-CC Bone Growth Stimulator and OrthoLogic® 1000 (Medium) Bone Growth Stimulator Supplement to PMA number P910066 | OrthoLogic, Corp. Phoenix, AZ 85034 | Received PMA in 1997 for the OrthoLogic 1000 single closed coil soft pack bone growth stimulator in sizes XS, S, M, L, and XL and for the OrthoLogic 1000 Bone Growth Stimulator in the medium size. The devices, as modified, will be marketed under the trade names OL 1000-CC and OL 1000 (medium) and are indicated for the noninvasive treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones, where the width of the nonunion defect is less than one-half the width of the bone to be treated.
OrthoLogic 1000-SC Bone Growth Stimulator Supplement to PMA number P910066 | OrthoLogic Corporation Tempe, AZ 85281 | Received PMA in 1998 for modifications to the sizes of the device. The device, as modified, will be marketed under the trade name OrthoLogic 1000-SC and is indicated for the noninvasive treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones. A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing.
OrthoLogic™ 1000 and CC Bone Growth Stimulator Supplement to PMA number P910066 | OrthoLogic Corporation Tempe, AZ 85281 | Received PMA in 1998 for a change in the indications-for-use language to state “The OrthoLogic 1000 Bone Growth Stimulator is indicated for the noninvasive treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones. A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing”; and “The OrthoLogic CC Bone Growth Stimulator is indicated for the noninvasive treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones. A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing.”
Physio-Stim I & II Model 6000 & 7000 Original PMA number P850007 | Orthofix, Inc. | Received PMA in 1986 as a non-invasive bone growth stimulator
Physio-Stim® Lite Models 202L, 303L, 404L, 313L, and 314L Supplement to PMA number P850007 | Orthofix, Inc. Richardson, TX 75081 | Received PMA in 1997 for modifications to the design and labeling of the Physio-Stim® Bone Growth Stimulator. The device, as modified, is to be marketed under the trade name Physio-Stim® Lite and is indicated for the treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones, where the width of the nonunion defect is less than one-half the width of the bone to be treated.
Physio-Stim Models 3202, 3302, 3313, 3314, 3315 Supplement to PMA number P850007 | Orthofix, Inc. McKinney, TX 75069 | Received PMA in 2005 to modify the Physio-Stim Lite, Models 202L, 303L, 215L, 313L, as follows:; 1. change the power source from a 9-volt disposable battery to an 11.1-volt rechargeable; 2. change the user interface from a three color LED to a backlit LCD display; 3. change the circuit assembly from separate boards for the drive circuit and microcontroller to a single board; 4. add an optional personal data assistant (PDA) that may be used to set daily shutdown time for Orthofix personnel use only; and; 5. change the serial port cable on the compliance printer to an infrared port.; The devices, as modified, will be marketed under the trade names Physio-Stim Models 3202, 3302, 3313, 3314, and 3315. The Physio-Stim Models are indicated for the treatment of an established nonunion acquired secondary to trauma, excluding vertebrae and all flat bones, where the width of the nonunion defect is less than one-half the width of the bone to be treated. A nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing.
Capacitive coupling systems
OrthoPak Bone Growth Stimulator Original PMA number P850022 | BioElectron | Received PMA in 1986
OrthoPak Bone Growth Stimulator System Supplement to PMA number P850022 | BioElectron (New Jersey), now part of EBI | Received PMA in 1998 for the following modifications:; 1. The “tombstone” - No Part Number; - a) Change of indication b)Minor grammatical corrections of labelling; 2. The Physician Manual - Part Number 380-0001-0001-844; a. Change of indication; b. Removed all references to “Snap-on Electrodes” (obsolete); c. Reduced the number of sizes of foam spacers provided from 2 to 1; d. Increased the number of leads provided from 2 to 3 (20” lead added); e. Minor grammatical corrections of labeling; 3. The Patient Manual - Part Number 380-0002-0001-844; a. Change of indication; b. Removed all references to “Snap-on Electrodes” (obsolete); c. Reduced the number of sizes of foam spacers provided from 2 to 1; d. Increased the number of leads provided from 2 to 3 (20” lead added); e. Added the section “Electrode Retainers” (copied \| from Physician Manual); f. Minor grammatical corrections; The indication change listed above in each section is as follows: removal of the reference to a 9 month clinical study time in the approved labels (“A non-union is considered to be established when a minimum of 9 months has elapsed since injury and the fracture site shows no visible progressive signs of healing for a minimum of 3 months - no change in fracture callus”) and to insert language as suggested in the FDA letter of June 3, 1998. (“A nonunion is considered to be established when the fracture site shows no visible progressive signs of healing.”) | (15)
Direct current systems
OsteoStim (R) Original PMA number P790005 | Electro-Biology, Inc., | Received PMA in 1980 as an invasive osteogenesis stimulator
OrthoGen®/OsteoGen™ Implantable Bone Growth Stimulator Supplement to PMA number P790005 | Electro-Biology, Inc., Parsippany, NJ 07054-1079 | Received PMA in 1998 for revision of the indications and usage section of the labeling to include the definition of nonunion recommended by the Orthopedic and Rehabilitation Devices Panel on April 28, 1998 and required per FDA’s letter dated June 3, 1998 (i.e., “a nonunion is considered to be established when the fracture site shows no visibly progressive signs of healing”).
Shock wave systems: No shock wave systems have received FDA approval for the treatment of nonunion fractures. The following are the shock wave devices that are approved by the FDA for other orthopedic indications.
HealthTronics OssaTron® Original PMA number P990086 | HealthTronics, Inc. Marietta, GA 30062 | Received PMA in 2000 for the OssaTron. The device is indicated for use for performing extracorporeal shock wave (ESW) treatment in patients with chronic proximal plantar fasciitis that has failed to respond to conservative treatment. Chronic proximal plantar fasciitis is defined as pain in the area of the insertion of the plantar fascia on the medial calcaneal tuberosity that has persisted for 6 months or more.
Siemens SONOCUR® Basic Original PMA number P010039 | Siemens Medical Solutions USA, Inc. Iselin, NJ 08830 | Received PMA in 2002 for the Siemens SONOCUR Basic. The Siemens SONOCUR Basic is a non-surgical alternative for the treatment of chronic lateral epicondylitis (commonly referred to as tennis elbow) for patients with symptoms of chronic lateral epicondylitis for 6 months or more and a history of unsuccessful conservative treatments.
Orthospec™ Extracorporeal Shock Wave Therapy Device Original PMA number P040026 | Medispec, Ltd. Germantown, MD 20874 | Received PMA in 2005 for the Orthospec Extracorporeal Shock Wave Therapy Device. The device is indicated for the treatment of Proximal Plantar Fasciitis with or without heel spur in patients 18 years of age or older. The Orthospec™ Extracorporeal Shock Wave Therapy is a non-invasive alternative method for patient with symptoms of proximal plantar fasciitis for 6 months or more and a history of unsuccessful conservative therapies to relieve heel pain. proximal plantar fasciitis is defined as heel pain in the area of the insertion of the plantar fascia on the plantar calcaneal tuberosity.