# Literature Searches

The clinical studies included in this report were identified using the algorithm shown in Figure A-1. The first stage of this multi-staged study selection process consisted of a comprehensive literature search. The second stage of the process consisted of the retrieval of all articles that met a set of a priori retrieval criteria. The final stage of the study selection algorithm consisted of the selection of the actual studies that form the evidence base for this report using a set of a priori inclusion criteria.

Figure A-1 Study Selection Algorithm

## Electronic Database Searches

The following databases have been searched for relevant information:

Cochrane Database of Systematic Reviews (through 2005, Issue 3)

Cochrane Registry of Clinical Trials (CENTRAL) (through 2005, Issue 3)

Cochrane Review Methodology Database (through 2005, Issue 3)

Database of Reviews of Effectiveness (Cochrane Library) (through 2005, Issue 3)

ECRI Health Devices Alerts (1977 through August 2005)

ECRI Health Devices Sourcebase (through August 2005)

ECRI Health Technology Forecast Database (through August 2005)

ECRI Healthcare Standards (1975 through August 2005)

ECRI International Health Technology Assessment Database (IHTA) (through August 2005)

ECRI Library Catalog (through August 2005)

ECRI TARGET (through August 2005)

Embase (1985 through August 15, 2005)

Lexis-Nexis, Healthcare News, Current (2003 – 2005)

PubMed (includes MEDLINE, HealthSTAR and CancerLit) (1975 through August 15, 2005)

U.S. Centers for Medicare & Medicaid Services (CMS) Web site (through August 2005)

U.S. Food and Drug Administration (FDA) Web site (through August 2005)

U.S. National Guideline Clearinghouse™ (NGC™) (through August 2005)

The search strategies employed a number of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts.

### Medical Subject Headings (MeSH) and Keywords

[underlined: Conventions:]

[mh] = MeSH heading

[majr] = MeSH heading designated as major topic

[pt] = Publication Type (PubMed)

[sb] = Subset of PubMed database (PreMedline, Systematic, OldMedline)

[sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)

[tiab] = keyword in title or abstract

[tw] = Text word

.de. = controlled vocabulary heading in OVID syntax (Emtree)

[underlined: Topic-Specific] | Non union
Bone void | Non-united
Fracture* | Non united
Fracture healing[mh] | Nonunion
Fracture fixation.de. | Nonunited
Fracture nonunion.de. | Ununited
Fractures[mh] | [underlined: Diagnosis]
Fractures, ununited[mh] | Diagnos*
Malaligned | Di[sh]
Malalignment | Di[sh]
Mal-union | [underlined: Etiology/Risk]
Malunion | Causality[mh]
Malunited | Causation
Non-union | Enabling factor*
Epidemiol* | Fracture fixation
Epidemiology[sh] | “Intention to treat”
Etiology[sh] | Manipulation, orthopedic[mh]
Predisposing factor* | OP-1
Risk factor* | Orthopedic fixation devices[mh]
Etiolog* | Orthopedic procedures[mh]
[underlined: Other] | Osteogenic protein*
Adult | Outcome assessment
[underlined: Therapy] | Proteins/therapeutic use[mh]
Biocompatible materials[mh] | Recombinant protein.de.
Biological response modifier.de. | Recombinant proteins/therapeutic use[mh]
Biologic response modifiers[mh] | rhBMP-7
Bmp-7 | rhOP-1
Bone graft* | Surgery
Bone matrix.de. | Surgery[sh]
Bone morphogenetic protein* | Surgical
Bone morphogenic protein* | Therapeutic*
Bone morphogenic proteins[mh] | Therapeutics[mh]
Bone regeneration.de. | Therapy
Bone stimulat* | Therapy[sh]
Bone substitut* | Treat*
Bone transplant* | Treatment*
Bone transplantation[mh] | Ultrasonic
Drug therapy[sh] | Ultrasonic therapy[mh]
Effectiveness | Ultrasound
Efficacy | [underlined: Devices (UMDNS)]
Electric stimulat* | Bolts, bone [16-077]
Electric stimulation therapy[mh] | Bone matrix implants, artificial [17-751]
Electrotherap* | Bone matrix implants, artificial [17-751]
ELF | Bone matrix implants, biological [17-756]
External fixation | Bone matrix implants, biological [17-756]
External fixators[mh] | Cement, orthopedic [12-830]
Grafts, bone [11-910] | Standards[sh]
Grafts, bone, synthetic [16-966] | “White paper”
Jaw fracture fixation devices [15-801] | Meta-analyses/Systematic Reviews:
Nails, bone [16-078] | Meta-analysis
Pins, bone [16-085] | Meta-analysis[mh]
Plates, bone [13-050] | Meta-analysis[pt]
Orthopedic external fixation systems [16-044] | “Systematic Review”
Orthopedic external fixation systems, fracture [15-767] | (evidence base* OR methodol* OR systematic* OR quantitative* OR studies OR overview*) AND review[pt]
Orthopedic internal fixation systems, fracture [12-833] | Randomized Controlled Trials:
Orthopedic internal fixation systems, other [16-031] | Crossover*
Screws, bone [16-101] | Cross-over*
Screws, bone [16-101] | Double-blind method[mh]
Staples, bone, compression, heat reshaping [20-327] | “Latin sauare”
Staples, bone, compression, separate-leg [20-326] | Placebo*
Staples, bone, compression, separate-leg [20-326] | Placebos[mh]
Tissue reconstructive materials, solid [16-153] | Random*[ti]
Tissue reconstructive materials, solid [16-153] | Random allocation[mh]
Wires, bone [16-104] | Randomized controlled trial[pt]
[underlined: Publication types] | Randomized controlled trials[mh]
Guidelines: | Single-blind method[mh]
“Clinical pathway” | ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask* OR blind* OR sham* OR dummy)
Consensus[ptj | ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask* OR blind* OR sham* OR dummy)
Guideline[pt]
Guideline*[ti]
“Policy statement”
“Position paper”
“Position statement”
Practice guidelines[mh]
“Practice parameter”
Standard*[ti]

The detailed strategy below is presented in PubMed syntax. Parallel strategies were used to search the Cochrane Library and Embase. Keyword searches were conducted in the other listed resources.

### PubMed Search Strategy (1975 – 2005)

Limited to English language, human population

Set Number | Concept | Search Statement
1 | Nonunion fracture | ((Fractures[mh] OR fracture healing[mh] OR fracture*[tw]) AND (ununited OR un-united OR “un united” OR nonunion OR “non union OR nonunion OR nonunited)) OR fractures, ununited[mh])
2 | Diagnosis and risk factors | #1 AND (diagnos*[tw] OR diagnosis[sh] OR etiolog*[tw] OR causation[tw] OR enabling factor*[tw] OR risk factor* OR predisposing factor*[tw] OR epidemiology[sh] OR epidemiol*[tw] OR etiology[sh] OR causality[mh])
3 | Treatment – general | #1 AND (th[sh] OR su[sh] OR dt[sh] OR effectiveness OR efficacy OR “intention to treat” OR treat OR treatment* OR therapy OR therapeutic* OR outcome assessment OR therapeutics[mh] OR surgery[tw] OR surgical[tw])
4 | Treatment – surgical | #1 AND (fracture fixation[mh] OR surgery[sh] OR surgery[tw] OR surgical[tw] OR orthopedic procedures[mh] OR bone graft* OR bone transplant* OR bone transplantation[mh] OR orthopedic fixation devices[mh] OR )
5 | Treatment – biologicals | #1 AND (biological response modifiers[mh] OR bmp-7 OR bone morphogeneic protein* OR bone morphogenetic proteins[mh] OR bone regeneration[mh] OR OP-1 OR osteogenic protein* OR proteins/tu[mh] OR recombinant proteins/tu[mh] OR rhBMP-7 OR rhOP-1 OR
6 | Treatment -stimulation | #1 AND (electric stimulation therapy[mh] OR bone stimulat* OR electric stimulat* OR electrotherap* OR ultrasonic therapy[mh] OR ultrason* OR ultrasound*)
7 | Treatment – other | #1 AND (biocompatible materials[mh] OR bone matrix OR bone substitut* OR external fixators[mh] OR external fixation OR manipulation, orthopedic[mh]
8 | Reviews, standards & guidelines | (st[sh] OR guideline[pt] OR consensus[pt] OR "practice parameter" OR "position statement" OR "position paper" OR "policy statement" OR standard*[ti] OR guideline*[ti] OR "white paper" OR "clinical pathway" OR practice guidelines[mh] OR meta-analysis OR meta-analysis[pt] OR ((evidence base* OR methodol* OR systematic* OR quantitativ* OR studies OR overview*) AND review[pt])))
9 | Background | #1 AND #8
10 | Combine sets | #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #9
11 | Limit publication types | NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case reports[pt] OR review[pt])
12 | Limit to human | AND (humans[mh] OR premedline[sb] OR publisher[sb])

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)