# EXECUTIVE SUMMARY

The Centers for Medicare and Medicaid Services (CMS) requested that AHRQ commission an evidence report to assist CMS and the Medicare Coverage Advisory Committee in considering treatments for nonunion fractures. On June 16th 2005, AHRQ issued a Statement of Work (SOW) contracting ECRI to prepare a report on the role of bone growth stimulating devices and orthobiologics in healing nonunion fractures. The SOW specified that ECRI perform a narrative review of background information and surgical therapy and a systematic review of bone growth stimulating devices and orthobiologics. For the systematic review, the tasks to be performed were the following:

1. Systematically search, review, and analyze the relevant scientific evidence for each question. Search MEDLINE and other suitable databases containing primary studies and review literature relevant to the questions to be addressed. Identify other sources of relevant literature, such as meeting abstracts and clinical trials currently in progress.
2. Retrieve and review full articles on eligible studies, assessing quality and extracting key data from each eligible study.
3. Prepare abbreviated evidence tables and summary of important findings.

In commissioning this report, AHRQ, in consultation with CMS and ECRI, developed six Key Questions to be addressed. Key Questions 1 through 5 were addressed by examining reviews, clinical practice guidelines, orthopedic textbooks and selected clinical studies published between 1990 and 2005. Key Question 6 was addressed by examining all eligible original clinical studies published between 1990 and 2005. The inclusion criteria for these studies are provided in the Methods section of this report. A draft report was submitted for review to a variety of interested parties, including representatives from orthopedic surgery, manufacturers of bone growth stimulating devices, AHRQ and CMS. This process resulted in a supplemental search for the period 1975 to 1990 to expand the information pertinent to electrical bone growth stimulating devices. Additional articles were identified by reviewers, and in one case, a translation of a study of ultrasound therapy published in German was provided to us.(1) Abstracts presented for the past 2 years at the American Academy of Orthopedic Surgeons (AAOS), the Orthopedic Trauma Association (OTA) and the American Orthopedic Foot and Ankle Society (AOFAS) meetings were reviewed to identify studies relevant to Key Question 6. Studies identified from the supplemental search and the meeting abstracts are discussed in the body of this report, but are not included in the full evidence tables in the Appendices.

The findings of our assessment as they pertain to the six Key Questions are presented below.

## Key Question 1 How is a nonunion fracture diagnosed?

There is no uniformly accepted method of nonunion diagnosis applicable to all fractures, given variations in the bone tissue and fracture characteristics. Even for fractures in a given bone, there is a range of opinions regarding the time by which a fracture is expected to heal. The term “delayed union” describes a fracture which has not healed within the expected time frame. Epidemiologic studies of time to healing of acute fractures with specific characteristics (e.g., open vs. closed) for specific bones could provide benchmarks. A full search and review of such studies was beyond the scope of the current report, but would probably be helpful to clinicians in defining delayed union. Once an assessment is made that healing is delayed, most authors define nonunion as the absence of signs of healing for an additional 3 months. One survey of orthopedic surgeons published in 2002 found that the mean and standard deviation (SD) time from initial fracture of the tibia to diagnosis of nonunion was 6 months (SD: 2 months), with a range of 2 to 12 months.(2)

There are variations in the specific radiographic and clinical criteria used to diagnose nonunion. Bhandari et al.(2) found that 79% of surgeons use radiographic evidence of cortical continuity as their primary means of defining nonunion fracture healing, but that 42% also used weight-bearing and 37% also use pain on palpation of the fracture site.

Multiple projections or computerized tomography (CT) may be necessary to identify evidence for healing. Magnetic resonance imaging (MRI) is useful for diagnosing infection complicating nonunion if the presence of hardware does not contravene its use.

Clinical characteristics favoring a diagnosis of nonunion include inability to bear weight, pain on palpation of the fracture site or motion at the site. These clinical findings in the absence of radiographic evidence for healing may influence the timing of diagnosis.

Despite these imaging and clinical methods, determination of the presence of nonunion can be very difficult and is often dependent on clinical judgment. Court-Brown’s discussion of the diagnosis of tibial nonunion is illustrative of the difficulty in diagnosis of nonunion.(3)

## Key Question 2 What are the risk factors for developing a nonunion fracture?

The principal reasons for fractures failing to unite are believed to be inadequate stabilization and failure of the biologic processes necessary for new bone formation. Both local and systemic factors may contribute to this breakdown in normal healing. Of the systemic risk factors, heavy smoking was mentioned in a number of reviews and studies as an important risk factor. Obesity, alcoholism, diabetes, peripheral vascular disease, and increasing age were also mentioned, although there is not agreement on the effect of age. Certain medications (e.g., corticosteroids) are also thought to increase risk for nonunion or infection, which in turn increases the risk for nonunion.

Certain characteristics of the fracture and the injury may predispose to nonunion. These include high-energy trauma, higher grade and open fractures, comminution of the fracture, vertical or oblique fracture pattern, and fracture displacement. Interposition of soft tissue between fragments impedes healing, and severe soft tissue trauma may interrupt vascular supply and may predispose to infection. Specific bones may have higher rates of nonunion than others because of limited normal blood supply or propensity to more severe fractures. Some techniques and hardware for fixation of acute fractures have been abandoned because of higher rates of nonunion, while new developments in acute fracture management have reduced the likelihood of nonunion with certain fractures.

## Key Question 3 What are the current standards of care for nonunion fractures?

### a What supportive measures are recommended?

Reviews of surgical management of nonunion mentioned supportive measures in the care of patients infrequently. Recommendations included control of infection, improvement in nutrition and smoking cessation. Good clinical practice dictates stabilizing any comorbid conditions such as diabetes prior to elective procedures.

### b What surgical therapies are currently recommended for treatment of nonunion?

Nonunions are classified as either septic (infected) or aseptic (noninfected), by clinical examination as either stiff or mobile, and by radiographic appearance as hypertrophic, oligotrophic or atrophic. Once nonunion has been diagnosed, the presence or absence of infection is a key determinant of treatment. In general, implantation of new hardware for stabilization may need to be delayed until antibiotic therapy and surgical debridement bring the infection under control. In some cases, previously implanted hardware must be removed. An external fixation device is sometimes used for stabilization of the fracture site in this setting. The fracture site is reassessed when the infection is under control.

Hypertrophic nonunions have viable bone ends and an adequate blood supply, but excessive motion at the fracture site has disrupted the healing process. Therapy of this type of nonunion emphasizes improving stabilization of the fracture site. Atrophic nonunions are those with a “biological” problem, i.e., a failure of the normal stimuli or cellular responses necessary for bone formation. Oligotrophic nonunions are intermediate in character between the hypertrophic and atrophic types. Both inadequate stability of the fracture site and impairment of the biological response to fracture play a role in many nonunions. Inadequate stability is most frequently addressed by use of fixation devices, either external or internal; biologic deficits are currently treated primarily by autogenous bone grafts. Autogenous bone grafts provide growth factors and cellular mechanisms for osteoinduction, but depend on adequate vascular supply at the nonunion site. In some instances, bone grafts are harvested with an intact vascular supply to overcome inadequate blood supply at the nonunion site, which is more likely with large defects. The iliac crest is the most commonly used donor site, although “local bone” may be obtained from a site close to the nonunion. Excessive morbidity, primarily related to the harvesting procedure, has led to a demand for alternative means of treatment. Patient preferences and values, as well as the assessment of higher levels of risk of complications from surgery, may also lead the orthopedic surgeon to consider less invasive methods of treatment.

### c What orthobiologics and external devices for stimulation of bone healing in nonunion fractures have been approved by the FDA and which have not been approved by the FDA?

The FDA considers most orthobiologicals to be Class II medical devices. Orthobiologics include resorbable calcium salt bone void fillers, some of which contain demineralized bone matrix (DBM). DBM is processed from human bone tissue and contains a variety of bone growth stimulators (osteoinductive agents such as bone morphogenetic proteins) and is used in a number of bone graft substitutes. Therefore, these products may be used in treating nonunion fractures as an FDA off-label use. One orthobiologic that is not classified as a Class II device is OP-1 Implant (Stryker Biotech). Stryker Biotech was granted a humanitarian device exemption (HDE) by the FDA for its use in treatment of recalcitrant long bone nonunions. Palacos E-Flow (Osteopal) Bone Cement (Biomet Merck) has FDA approval for femoral nonunions. Of note, autogenous bone graft and bone marrow aspirate, used to stimulate bone growth, are not regulated by the FDA.

Currently, a number of electrical stimulation devices and ultrasound devices have been approved by the FDA for treating nonunion fractures. Shock wave treatment has not been approved by the FDA. Several studies performed in Europe have examined the efficacy of this treatment for nonunion fractures.

## Key Question 4 What are the intermediate and patient-reported outcomes of treatment for nonunions, and how are they defined?

Three radiographic variables are most often used to determine nonunion fracture healing: callus size, cortical continuity, and progressive loss of fracture line. The ability of the patient to bear weight on the fractured limb and pain at the fracture site on palpation are additional nonradiographic methods often used to judge nonunion fracture healing. There is, however, a lack of consensus among surgeons as to which methods should be used to judge healing of fractures and to monitor response to treatment of nonunion. Cortical continuity is believed to be most directly related to return of original bone strength while callus size is the least related. However, cortical continuity may not be directly correlated with functional outcomes. Studies that use a combination of radiographic and clinical evidence of healing provide a more complete picture of the healing process than studies that use only radiographic evidence or only clinical evidence. A list of outcomes and measures used to assess them in the included studies is provided in Appendix C.

## Key Question 5 What is the evidence for variations in outcomes attributable to surgeon, procedure and institution characteristics?

We identified no publications that directly addressed this question.

## Key Question 6 What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

Fracture healing relies on a coordinated series of phases in which damaged nonfunctional tissue is replaced by tissue that restores the original structure and function of the bone. Each phase in the healing sequence relies on specific growth factors to ensure complete healing and bone restoration. Application of these growth factors directly into the fracture has been proposed as a means of enhancing bone repair. In bone tissue, these growth factors stimulate the production of cells needed in the healing process.

Another element in the repair process is the type of stress applied to the bone during healing. Biophysical stimulation has been proposed as a key element in repairing, maintaining, and remodeling of bone to meet its functional demands. However, the direct link between biophysical stimulation and the cellular responses controlled by the various growth factors has not been fully elucidated. The biophysical stimulation needed to enhance fracture healing may be supplied through external energy sources such as ultrasound, pulsed electromagnetic field stimulation (PEMF), low power direct current, and extracorporeal shock wave stimulation. Although these are all forms of biophysical stimulation, whether these modalities produce different cellular responses or follow a similar osteogenic pathway is still controversial.(4)

We identified 24 studies published from 1990 to 2005 that examined the effectiveness of bone growth stimulating devices or orthobiologics that met our inclusion criteria. These studies consisted of three studies of ultrasound, seven studies of PEMF, four studies of direct current and capacitive coupling, six studies of shock wave, and four studies of orthobiologics. We identified only four randomized controlled trials (RCT), two for PEMF, one for capacitative coupling and one for orthobiologics. We included case series in this report based on the prevalent belief that nonunion fractures are not likely to heal without intervention (see discussion in the Background section). Some of the reviewers of the draft of this report preferred to describe these as “self-paired patient controlled” studies – with each patient serving as his or her own control.(5–8) For the purpose of this report, however, we have considered these studies with no separate comparison group to be case series rather than controlled trials.

Three cases series published since 1990 (two prospective(1,9) and one retrospective(10)) using the Exogen system to treat nonunion in 1446 patients consistently reported that a high percentage of nonunions healed during ultrasound therapy. While the results of these studies suggest that ultrasound promotes the healing of nonunion fractures, they do not rule out a role for other concurrent treatment procedures, such as stabilization of the nonunion, contributing to the observed effects. The two studies reporting data for patients over 65 are not in agreement as to the effect of age on response to ultrasound treatment.

Seven studies published since 1990 with a total of 403 patients reported data concerning PEMF treatment of nonunions. Two of the included studies were double-blind RCTs using dummy devices and blinded assessment. One RCT examined longstanding tibial nonunions, comparing an active vs. dummy PEMF device in addition to treatment with a fibular osteotomy and unilateral external fixation. The healing rate was higher in the group receiving PEMF in addition to the other treatment, but was not statistically significantly different after adjustment for confounding by the greater proportion of smokers in the control group.(11) The second RCT compared an active vs. dummy PEMF device and full-leg plaster cast immobilization in patients with “delayed tibial union” (failure to heal within 16 – 32 weeks of initial injury while treated with cast immobilization).(12) While radiographic assessments demonstrated significantly greater progression toward healing in the active device group at the end of the 12 week study, analysis of the long-term follow-up data was confounded by early surgical and electrical device intervention in the control group; longer followup prior to further intervention may have altered the difference between the groups. Nonetheless, 17 of 20 patients treated with the active device from the beginning of the 12-week study had healed at long-term followup without the need for further surgical intervention.(13) One nonrandomized study with a concurrent control group demonstrated higher rates of healing in the PEMF group with infected nonunions, but no adjustments were made for differences in patient and fracture characteristics in the two groups.(14) One prospective case series which included patients with nonunions of long duration also reported healing in 57%. The remaining case series showed healing when PEMF therapy was combined with cast immobilization. Studies conducted prior to 1990 were consistent with the more recent studies in terms of healing rates. Overall, these results consistently indicate that nonunions heal in patients treated with PEMF, but the effect of PEMF cannot be separated from the effect of concomitant fracture site stabilization.

We identified four studies published since 1990 with a total of 351 patients treated with direct current or capacitive coupling treatment of nonunions. An RCT examined patients with established nonunions treated with an active capacitive coupling device (n = 10) or an inactive device (n = 11).(15) While 6 of 10 in the active treatment group healed in an average of 21 weeks compared to none of the control group, there were 5 tibial nonunions of 10 total nonunions in the active treatment group, vs. 10 tibial nonunions out of 11 total nonunions in the control group.(15) This may have negatively affected the healing rates in the control group. One retrospective comparative study examined tibial nonunions in separate groups of patients treated with direct current, capacitive coupling, and bone graft.(16) This study used logistic regression analysis to estimate better than 95% healing with all three treatments when the nonunions were of 10-month duration prior to treatment and no other risk factors for failure to respond to the treatments were present. Risk factors predicting slower healing rates included longer duration of nonunion prior to treatment, open fracture, comminuted fracture, prior failed bone graft or prior failed electrical therapy. Patient age was used as a continuous variable in the logistic regression analysis, but any influence of age on healing was not reported in the study. In the remaining two studies, one specifically examined patients with large nonunion gaps (>1 cm, which is wider than is typical for nonunions treated with electrical stimulation).(17) The other study reported on the 10-year followup of patients treated with an implanted bone growth stimulator, but forty-four percent of the original patients were not located, reducing the validity of the reported results.(18) An additional 6 case series published between 1975 and 1989 had reported healing rates between 40% and 90%. Overall, these studies consistently demonstrate healing during treatment with direct current and capacitative coupling but the effect of these therapies cannot be separated from the effect of concomitant immobilization of the fracture site.

Six case series published since 1990 with a total of 430 patients reported results of shock wave treatment of nonunions of multiple bone types.(19–22) Five of the studies were conducted in Europe and one was conducted in Taiwan; shock wave devices have not been approved by the FDA for use in treating nonunion fractures. These case series reported healing rates between 50% and 80%, but the effect of shock wave therapy cannot be separated from the effect of immobilization in these uncontrolled studies.

Four separate studies published since 1990 with a total of 214 patients reported data concerning the use of orthobiologics to treat nonunions. One study was an RCT comparing BMP-7, OP-1 Implant (Stryker Biotech) to fresh bone autograft in the treatment of tibial nonunions. Stryker Biotech was granted a humanitarian device exemption (HDE) by the FDA for the use of OP-1 Implant as an alternative to autograft in recalcitrant long bone nonunions where use of autograft is not feasible and alternative treatments have failed. Patients in both groups underwent intramedullary rod fixation in addition to the autograft or OP-1 grafting procedure.(23) The internal validity of this study was rated as “fair” only because autogenous bone grafting requires removal of bone from the patient’s pelvis; consequently, patients could not be blinded to treatment. However, radiographic assessment of bone bridging was blinded. The study found similar healing rates in the two groups. A noninferiority statistical analysis should be performed to determine whether OP-1 Implant in conjunction with internal fixation was not inferior to autogenous bone graft in the treatment of tibial nonunions. Assuming the analysis demonstrates noninferiority, this single study would need to be replicated by other investigators before OP-1 is considered an effective substitute for autogenous bone grafting. The absence of the morbidity associated with harvesting of autogenous bone for grafting is a distinct advantage; hence, additional studies would only need to demonstrate noninferiority as well.

The other three studies of orthobiologics were retrospective case series. One examined the use of AlloMatrix Injectable Putty (Wright Medical Technology) in nonunions in multiple bone types.(24) AlloMatrix Putty, which contains demineralized bone matrix (Allogro from AlloSource), carboxymethylcellulose, and OsteoSet (calcium sulfate), is cleared by the FDA only for “bony voids or gaps that are not intrinsic to the stability of bony structure” and is therefore not directly cleared for use in nonunion fractures. The publication did not report prior treatment or the duration of the nonunions prior to the AlloMatrix Putty treatment. Without this information, interpretation of the results is difficult. The remaining two studies were retrospective case series from a single laboratory that examined the use of a composite allograft with partially purified human bone morphogenetic protein (hBMP) to treat nonunions of the femur in one study, and multiple bone types in the other. As with other case series, the precise role of the composite allograft in the healing process cannot be distinguished from the other procedures used to stabilize the limbs. Two recent meeting abstracts describing studies utilizing DBM indicated healing rates of 54% and 75%, respectively, but one found high rates of wound drainage and subsequent deep infection.(25,26) Additional studies are needed to understand the role of DBM in treating nonunions at this time.

### Concluding Remarks

What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

After searching the literature published since 1990, retrieving references, and applying our inclusion/exclusion criteria, we identified 24 published studies of bone growth stimulators and orthobiologics. Four of the studies were RCTs, two were retrospective comparison studies, seven were prospective case series, and the remaining 11 were retrospective case series. Thus, the overall quality of the evidence for each type of intervention is for the most part low, and few of the studies can actually be used to distinguish the effect of the device or orthobiologics agent from the additional treatments these patients received. While some view case series of patients treated for nonunion as “self-paired, patient controlled” studies, the occurrence of healing at late timepoints in some patients receiving other therapies (e.g., cast immobilization) made us hesitant to view the studies in this way. Two RCTs of PEMF therapy indicate that patients treated with PEMF had healing of nonunions, but the results from one study did not reach statistical significance after adjusting for confounding, and the other was only randomized for the initial 12 weeks of treatment and observation.(11,12) One prospective case series,(27) a retrospective series with a comparison group(14) and three retrospective case series also demonstrated healing with PEMF treatment, but the effect of PEMF could not be separated from the contribution of the immobilization procedures or casting.(11) The RCT of treatment with a capacitative coupling device demonstrated higher rate of healing in the active treatment group, although the number of tibial nonunions in the comparison group may have negatively affected the results in that group.(15) The remaining RCT, Friedlaender et al.,(23) indicates that OP-1 Implant may substitute for autogenous bone graft in the treatment of tibial nonunions in patients also being treated with reamed intramedullary nail fixation, but a noninferiority statistical analysis is needed to show that OP-1 (along with internal fixation) is not inferior to autogenous bone graft and additional studies are needed to replicate the results. Case series studies of ultrasound and shock wave therapy report healing of nonunions with these therapies but individual study quality limits the strength of the evidence and the effects cannot be separated from those of concomitant treatments. There is some indication from case series that DBM preparations are also useful, but additional studies are needed to understand the role of DBM in treating nonunion.

The studies’ generalizability to the Medicare population was poor with few studies either reporting results separately for individuals 65 years of age or older or analyzing results by age groups. It is commonly argued that there is no change in healing response with increasing age,(5–7) but whether this holds true across the lifespan (even in the absence of comorbid conditions that predispose to impaired healing) is not evident from the literature we examined. The higher prevalence of osteoporosis in older adults complicates the management of nonunion by reducing the likelihood of successful stabilization with internal fixation.(28,29) Whether the results of treatments in younger adults can be generalized to persons of advanced age is not entirely clear, but reporting of outcomes separately for older patients in studies of nonunion treatments would provide useful information.