# BIBLIOGRAPHY

1 Mayr E, Mockl C, Lenich A, Ecker M, Ruter A. [Is low intensity ultrasound effective in treatment of disorders of fracture healing?]. Unfallchirurg. Feb. 2002;105(2):108-115. [pmid: 11968536].
2 Bhandari M, Guyatt GH, Swiontkowski MF, Tornetta P 3rd, Sprague S, Schemitsch EH. A lack of consensus in the assessment of fracture healing among orthopaedic surgeons. J Orthop Trauma. Sep. 2002;16(8):562-566. [pmid: 12352564].
3 Court-Brown CM. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Fractures of the tibia and fibula. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:19392000.
4 Chao EY, Inoue N. Biophysical stimulation of bone fracture repair, regeneration and remodelling. Eur Cell Mater. Dec. 31. 2003;6:72-84. discussion 84-5. [pmid: 14722904].
5 Henry DM. Personal communication. Aug. 22. 2005:33.
6 Simon B. (Director of Research, Orthopaedic Research Society). Personal communication. Aug. 22. 2005:17.
7 Galie E. (Director, Clinical Research, Orthofix, Inc.). Personal communication. Aug. 22. 2005:98.
8 Pounder N. (Senior Research Project Manager, Chartered Physicist, Member of the Institute of Physics, Smith & Nephew Orthopaedics. Memphis, TN). Personal communication. Aug. 26. 2005:11.
9 Nolte PA, van der Krans A, Patka P, Janssen IM, Ryaby JP, Albers GH. Low-intensity pulsed ultrasound in the treatment of nonunions. J Trauma. Oct. 2001;51(4):693-702. discussion 702-3. [pmid: 11586161].
10 Mayr E, Frankel V, Ruter A. Ultrasound--an alternative healing method for nonunions. Arch Orthop Trauma Surg. 2000;120(1-2):1-8. [pmid: 10653095].
11 Simonis RB, Parnell EJ, Ray PS, Peacock JL. Electrical treatment of tibial non-union: a prospective, randomised, double-blind trial. Injury. May. 2003;34(5):357-362. [pmid: 12719164].
12 Sharrard WJ. A double-blind trial of pulsed electromagnetic fields for delayed union of tibial fractures. J Bone Joint Surg Br. May. 1990;72(3):347-355. [pmid: 2187877].
13 Sharrard WJW. (Professor Associate of Orthopaedic Surgery, University of Sheffield and Emeritus Consultant Orthopaedic Surgeon). Personal communication. Jun. 15. 1993:9.
14 Traina GC, Fontanesi G, et al. Effect of electromagnetic stimulation on patients suffering from non-union. J Bioelectr. 1991;10(1-2):101-117.
15 Scott G, King JB. A prospective, double-blind trial of electrical capacitive coupling in the treatment of non-union of long bones. J Bone Joint Surg Am. Jun. 1994;76(6):820-826. [pmid: 8200888].
16 Brighton CT, Shaman P, Heppenstall RB, Esterhai JL Jr, Pollack SR, Friedenberg ZB. Tibial nonunion treated with direct current, capacitive coupling, or bone graft. Clin Orthop Relat Res. Dec. 1995;(321):223-234. [pmid: 7497673].
17 Zamora-Navas P, Borras Verdera A, Antelo Lorenzo R, Saras Ayuso JR, Pena Reina MC. Electrical stimulation of bone nonunion with the presence of a gap. Acta Orthop Belg. 1995;61(3):169-176. [pmid: 8525812].
18 Cundy PJ, Paterson DC. A ten-year review of treatment of delayed union and nonunion with an implanted bone growthstimulator. Clin Orthop Relat Res. Oct. 1990;(259):216-222. [pmid: 2208859].
19 Biedermann R, Martin A, Handle G, Auckenthaler T, Bach C, Krismer M. Extracorporeal shock waves in the treatment of nonunions. J Trauma. May. 2003;54(5):936-942. [pmid: 12777907].
20 Rompe JD, Rosendahl T, Schollner C, Theis C. High-energy extracorporeal shock wave treatment of nonunions. Clin Orthop Relat Res. Jun. 2001;(387):102-111. [pmid: 11400870].
21 Schaden W, Fischer A, Sailler A. Extracorporeal shock wave therapy of nonunion or delayed osseous union. Clin Orthop Relat Res. Jun. 2001;(387):90-94. [pmid: 11400900].
22 Valchanou VD, Michailov P. High energy shock waves in the treatment of delayed and nonunion of fractures. Int Orthop. 1991;15(3):181-184. [pmid: 1743828].
23 Friedlaender GE, Perry CR, Cole JD, Cook SD, Cierny G, Muschler GF, Zych GA, Calhoun JH, LaForte AJ, Yin S. Osteogenic protein-1 (bone morphogenetic protein-7) in the treatment of tibial nonunions: a prospective, randomized clinical trial comparing rhOP-1 with fresh bone autograft. J Bone Joint Surg Am. 2001;83(Suppl 1 Pt 2):S151-S158. [pmid: 11314793].
24 Wilkins RM, Kelly CM. The effect of allomatrix injectable putty on the outcome of long bone applications. Orthopedics. May. 2003;26(5 Suppl):s567-s570. [pmid: 12755227].
25 Ziran BH, Smith WR, Lahti Z, Williams A. Use of calcium-based demineralized bone matrix (DBM) allograft product for nonunions and posttraumatic reconstruction of the appendicular skeleton: preliminary results and complications [paper No. 64]. Hippocrates Winslow & Babbage Foundation 2004 Annual Meeting. March 11, 2004. San Francisco (CA). 2004. Also available: http://www.hwbf.org/ota/am/ota04/otapa/OTA041164.htm.
26 Coupe KJ, Moore FN, Veurink R. The use of a demineralized bone matrix - bone marrow aspirate composite graft in the treatment of high energy fracture nonunions [poster no. 88]. Hippocrates Winslow & Babbage Foundation 2003 Annual Meeting. February 6, 2003. New Orleans (LA). 2003. Also available: http://www.hwbf.org/ota/am/ota03/otapo/OTP03088.htm.
27 Garland DE, Moses B, Salyer W. Long-term follow-up of fracture nonunions treated with PEMFs. Contemp Orthop. Mar. 1991;22(3):295-302. [pmid: 10147555].
28 Harris MB. (Chief, Orthopaedic Trauma, Brigham and Women's Hospital, Boston MA). Personal communication. Aug. 26. 2005:1.
29 Chao EY, Inoue N, Koo TK, Kim YH. Biomechanical considerations of fracture treatment and bone quality maintenance in elderly patients and patients with osteoporosis. Clin Orthop Relat Res. Aug. 2004;(425):12-25. [pmid: 15292783].
30 Wiss DA, Stetson WB. Tibial nonunion: treatment alternatives. J Am Acad Orthop Surg. Oct. 1996;4(5):249-257. [pmid: 10797192].
31 Muschler GF. (Orthopaedic Surgery & Biomedical Engineering, The Cleveland Clinic Foundation, Cleveland, OH). Personal communication. Sep. 2. 2005:7.
32 Buckwalter JA, Einhorn TA, Marsh JL. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Bone and joint healing. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:245-272.
33 Childs SG. Stimulators of bone healing. Biologic and biomechanical. Orthop Nurs. Nov-Dec. 2003;22(6):421-428. [pmid: 14705472].
34 Einhorn TA. Enhancement of fracture healing. Instr Course Lect. 1996;45:401-416. [pmid: 8727759].
35 Saleh KJ, Hak DJ. Socioeconomic burden of traumatic tibial fractures: nonunion or delayed union. Medscape [internet]. New York (NY). WebMD Corporation. Aug. 28. [cited 2003 Mar 12]. 2001:19. Available: http://www.medscape.com.
36 Connolly JF. Tibial nonunion: diagnosis and treatment. Park Ridge (IL). American Academy of Orthopaedic Surgeons. 1991:71.
37 Einhorn TA. The cell and molecular biology of fracture healing. Clin Orthop Relat Res. Oct. 1998;(355 Suppl):S7-S21. [pmid: 9917622].
38 Rodriguez-Merchan EC, Forriol F. Nonunion: general principles and experimental data. Clin Orthop Relat Res. Feb. 2004;(419):4-12. [pmid: 15021125].
39 Reed AA, Joyner CJ, Brownlow HC, Simpson AH. Human atrophic fracture non-unions are not avascular. J Orthop Res. May. 2002;20(3):593-599. [pmid: 12038636].
40 Barnes GL, Kostenuik PJ, Gerstenfeld LC, Einhorn TA. Growth factor regulation of fracture repair. J Bone Miner Res. Nov. 1999;14(11):1805-1815. [pmid: 10571679].
41 Hernigou P, Poignard A, Beaujean F, Rouard H. Percutaneous autologous bone-marrow grafting for nonunions: influence of the number and concentration of progenitor cells. J Bone Joint Surg Am. 2005;87(7):1430-1437. [pmid: 15995108].
42 Wu CC, Chen WJ. Treatment of femoral shaft aseptic nonunions: comparison between closed and open bone-grafting techniques. J Trauma. Jul. 1997;43(1):112-116. [pmid: 9253919].
43 Wu CC, Shih CH, Chen WJ, Tai CL. Effect of reaming bone grafting on treating femoral shaft aseptic nonunion after plating. Arch Orthop Trauma Surg. 1999;119(5-6):303-307. [pmid: 10447628].
44 Praemer A, Furner S, Rice DP. Musculoskeletal conditions in the United States. Rosemont (IL). American Academy of Orthopaedic Surgeons. Frequency of occurrence. 1999:83-87.
45 2002 National statistics: patient and hospital characteristics for ICD-9-CM all-listed diagnosis code 733.82 nonunion of fractures. [internet]. Rockville (MD). Agency for Healthcare Research and Quality. [cited 2005 Jun 21]. 2002:1. Available: http://hcup.ahrq.gov/HcupNet.asp.
46 Healthcare Cost & Utilization Project (HCUP). [Web site]. Rockville (MD). Agency for Healthcare Research and Quality. 2004. [updated 2005 Jun 17]. [cited 2004 Sep 30]. [various]. Available: http://www.ahrq.gov/data/hcup/.
47 Dieppe P, Tobias J. Tallis R, Fillit H, Brocklehurst JC, editors. Bone and joint aging. Brocklehurst's textbook of geriatric medicine and gerontology. 5th ed. London (UK). Churchill Livingstone. 1998:1131-1135.
48 Dempster DW. The pathophysiology of bone loss. Clin Geriatr Med. May. 2003;19(2):259-270. [pmid: 12916285].
49 Kohrt WM. Aging and the osteogenic response to mechanical loading. Int J Sport Nutr Exerc Metab. Dec. Suppl. 2001;11:S137-S142. [pmid: 11915912].
50 Troen BR. Molecular mechanisms underlying osteoclast formation and activation. Exp Gerontol. Jun. 2003;38(6):605-614. [pmid: 12814795].
51 Chan GK, Duque G. Age-related bone loss: old bone, new facts. Gerontology. Mar-Apr. 2002;48(2):62-71. [pmid: 11867927].
52 Street JT, Wang JH, Wu QD, Wakai A, McGuinness A, Redmond HP. The angiogenic response to skeletal injury is preserved in the elderly. J Orthop Res. 2001;19(6):1057-1066. [pmid: 11781005].
53 Harris MB. (Chief, Orthopaedic Trauma, Brigham and Women's Hospital, Boston MA). Personal communication. Jul. 14. 2005:2.
54 Bucholz RW, Heckman JD, editors. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2 v. 2002:2262.
55 Newcombe RG. Interval estimation for the difference between independent proportions: comparison of eleven methods. Stat Med. Apr. 30. 1998;17(8):873-890. [pmid: 9595617].
56 Armitage P, Berry G. Statistical methods in medical research. 3rd ed. Oxford, England. Blackwell Scientific. 1994:620.
57 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, Atkins D. Current methods of the U.S. Preventive Services Task Force. A review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
58 Smith WR, Shank JR, Skinner HB, Diao E, Lowenberg DW. Skinner HB, editor. Musculoskeletal trauma surgery. Current diagnosis & treatment in orthopedics. 3rd ed. Columbus (OH). McGraw-Hill Medical Publishing. Jun. 2003:55-124.
59 Ring D. Malunion and nonunion of the metacarpals and phalanges. J Bone Joint Surg Am. Jun. 2005;87-A(6):1380-1388.
60 Mathews V, Cabanela ME. Femoral neck nonunion treatment. Clin Orthop Relat Res. Feb. 2004;(419):57-64. [pmid: 15021132].
61 Maffulli N, Thornton A. Ultrasonographic appearance of external callus in long-bone fractures. Injury. Jan. 1995;26(1):5-12. [pmid: 7868211].
62 Chen F, Osterman AL, Mahony K. Smoking and bony union after ulna-shortening osteotomy. Am J Orthop. Jun. 2001;30(6):486-489. [pmid: 11411875].
63 Adams CI, Keating JF, Court-Brown CM. Cigarette smoking and open tibial fractures. Injury. Jan. 2001;32(1):61-65. [pmid: 11164405].
64 Hak DJ, Lee SS, Goulet JA. Success of exchange reamed intramedullary nailing for femoral shaft nonunion or delayed union. J Orthop Trauma. Mar-Apr. 2000;14(3):178-182. [pmid: 10791668].
65 Schmitz MA, Finnegan M, Natarajan R, Champine J. Effect of smoking on tibial shaft fracture healing. Clin Orthop Relat Res. Aug. 1999;(365):184-200. [pmid: 10627703].
66 Kyro A, Usenius JP, Aarnio M, Kunnamo I, Avikainen V. Are smokers a risk group for delayed healing of tibial shaft fractures?. Ann Chir Gynaecol. 1993;82(4):254-262. [pmid: 8122874].
67 Volgas DA, Stannard JP, Alonso JE. Nonunions of the humerus. Clin Orthop Relat Res. Feb. 2004;(419):46-50. [pmid: 15021130].
68 Prommersberger KJ, Fernandez DL. Nonunion of distal radius fractures. Clin Orthop Relat Res. Feb. 2004;(419):51-56. [pmid: 15021131].
69 Giannoudis PV, MacDonald DA, Matthews SJ, Smith RM, Furlong AJ, De Boer P. Nonunion of the femoral diaphysis. The influence of reaming and non-steroidal anti-inflammatory drugs. J Bone Joint Surg Br. Jul. 2000;82(5):655-658. [pmid: 10963160].
70 Cox MA, Dolan M, Synnott K, McElwain JP. Closed interlocking nailing of humeral shaft fractures with the Russell-Taylor nail. J Orthop Trauma. Jun-Jul. 2000;14(5):349-353. [pmid: 10926243].
71 Gainor BJ, Moussa F, Schott T. Healing rate of transverse osteotomies of the olecranon used in reconstruction of distal humerus fractures. J South Orthop Assoc. Winter. 1995;4(4):263-268. [pmid: 8925380].
72 O'Dwyer KJ, Chakravarty RD, Esler CN. Intramedullary nailing technique and its effect on union rates of tibial shaft fractures. Injury. Sep. 1994;25(7):461-464. [pmid: 7960051].
73 Larsen LB, Madsen JE, Hoiness PR, Ovre S. Should insertion of intramedullary nails for tibial fractures be with or without reaming? A prospective, randomized study with 3.8 years' follow-up. J Orthop Trauma. Mar. 2004;18(3):144-149. [pmid: 15091267].
74 Pugh DM, McKee MD. Advances in the management of humeral nonunion. J Am Acad Orthop Surg. Jan-Feb. 2003;11(1):4859.
75 Gonzalez del Pino J, Bartolome del Valle E, Grana GL, Villanova JF. Free vascularized fibular grafts have a high union rate in atrophic nonunions. Clin Orthop Relat Res. Feb. 2004;(419):38-45. [pmid: 15021129].
76 Harley BJ, Beaupre LA, Jones CA, Dulai SK, Weber DW. The effect of time to definitive treatment on the rate of nonunion and infection in open fractures. J Orthop Trauma. Aug. 2002;16(7):484-490. [pmid: 12172278].
77 Harris MB. (Chief, Orthopaedic Trauma, Brigham and Women's Hospital, Boston MA). Personal communication. Apr. 15. 2005:1.
78 ECRI. Recombinant human osteogenic protein-1 (rhOP-1) for healing nonunion fractures of the tibia. Plymouth Meeting (PA). ECRI Health Technology Assessment Information Service. Jan. 2005:54. (Windows on medical technology; no. 122).
79 Seiler JG 3rd, Johnson J. Iliac crest autogenous bone grafting: donor site complications. J South Orthop Assoc. Summer. 2000;9(2):91-97. [pmid: 10901646].
80 Younger EM, Chapman MW. Morbidity at bone graft donor sites. J Orthop Trauma. 1989;3(3):192-195. [pmid: 2809818].
81 Ahlmann E, Patzakis M, Roidis N, Shepherd L, Holtom P. Comparison of anterior and posterior iliac crest bone grafts in terms of harvest-site morbidity and functional outcomes. J Bone Joint Surg Am. May. 2002;84-A(5):716-720. [pmid: 12004011].
82 Zlowodzki M, Obremskey WT, Thomison JB, Kregor PJ. Functional outcome after treatment of lower-extremity nonunions. J Trauma. Feb. 2005;58(2):312-317. [pmid: 15706193].
83 Chandler RW. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Principles of internal fixation. Rockwood and Green's fracture in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:181-230.
84 Wu LC, Renucci JD, Song DH. Sternal nonunion: a review of current treatments and a new method of rigid fixation. Ann Plast Surg. Jan. 2005;54(1):55-58. [pmid: 15613884].
85 Lazarus MD. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Fractures of the clavicle. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:1041-1078.
86 Robinson CM. Fractures of the clavicle in the adult. Epidemiology and classification. J Bone Joint Surg Br. May. 1998;80(3):476-484. [pmid: 9619941].
87 Rokito AS, Zuckerman JD, Shaari JM, Eisenberg DP, Cuomo F, Gallagher MA. A comparison of nonoperative and operative treatment of type II distal clavicle fractures. Bull Hosp Jt Dis. 2002-2003;61(1-2):32-39. [pmid: 12828377].
88 Rodriguez-Merchan EC, Gomez-Castresana F. Internal fixation of nonunions. Clin Orthop Relat Res. Feb. 2004;(419):13-20. [pmid: 15021126].
89 Jones GL, McCluskey GM 3rd, Curd DT. Nonunion of the fractured clavicle: evaluation, etiology, and treatment. J SouthOrthop Assoc. Spring. 2000;9(1):43-54.
90 Harris MB. (Chief, Orthopaedic Trauma, Brigham and Women's Hospital, Boston MA). Personal communication. Aug. 17. 2005:16.
91 Gregory PR Jr. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Fractures of the shaft of the humerus. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:973-996.
92 Ring D, Jupiter JB, Quintero J, Sanders RA, Marti RK. Atrophic ununited diaphyseal fractures of the humerus with a bonydefect: treatment by wave-plate osteosynthesis. J Bone Joint Surg Br. Aug. 2000;82(6):867-871. [pmid: 10990313].
93 Patel VR, Menon DK, Pool RD, Simonis RB. Nonunion of the humerus after failure of surgical treatment. Management using the Ilizarov circular fixator. J Bone Joint Surg Br. Sep. 2000;82(7):977-983. [pmid: 11041585].
94 Strauss E, Bartlett CS III, Casden A, DiGiovanni G, Frieden RA, Hahn M, Karas E, Plate AM, Sweet S. Tallis R, Fillit H, Brocklehurst JC, editors. Orthopaedic geriatrics. Brocklehurst's textbook of geriatric medicine and gerontology. 5th ed. London (UK). Churchill Livingstone. 1998:1189-1223.
95 Ring D. Treatment of the neglected distal radius fracture. Clin Orthop Relat Res. Feb. 2005;(431):85-92. [pmid: 15685060].
96 Munk B, Larsen CF. Bone grafting the scaphoid nonunion: a systematic review of 147 publications including 5,246 cases of scaphoid nonunion. Acta Orthop Scand. Oct. 2004;75(5):618-629. [pmid: 15513497].
97 Mears DC, Velyvis J. Surgical reconstruction of late pelvic post-traumatic nonunion and malalignment. J Bone Joint Surg Br. Jan. 2003;85(1):21-30. [pmid: 12585573].
98 Starr AJ, Bucholz RW. Bucholz RW, Heckman JD, Rockwood CA, Green DP, editors. Fractures in the shaft of the femur. Rockwood and Green's fractures in adults. 5th ed. Philadelphia (PA). Lippincott Williams & Wilkins. 2001;Vol. 1:16831730.
99 Goulet JA, Templeman D. Delayed union and nonunion of tibial shaft fractures. Instr Course Lect. 1997;46:281-291. [pmid: 9143973].
100 Moed BR, Watson JT. Intramedullary nailing of aseptic tibial nonunions without the use of the fracture table. J Orthop Trauma. Apr. 1995;9(2):128-134. [pmid: 7776032].
101 Richmond J, Colleran K, Borens O, Kloen P, Helfet DL. Nonunions of the distal tibia treated by reamed intramedullary nailing. J Orthop Trauma. Oct. 2004;18(9):603-610. [pmid: 15448449].
102 Riemer BL, Sagiv S, Butterfield SL, Burke CJ 3rd. Tibial diaphyseal nonunions after external fixation treated with nonreamed solid core nails. Orthopedics. Feb. 1996;19(2):109-116. [pmid: 8834286].
103 Gudas CJ, Cann JE. Complications of foot surgery. Nonunions and related disorders. Clin Podiatr Med Surg. Apr. 1991;8(2):321-339. [pmid: 1676342].
104 Rosenberg GA, Sferra JJ. Treatment strategies for acute fractures and nonunions of the proximal fifth metatarsal. J Am Acad Orthop Surg. Sep-Oct. 2000;8(5):332-338. [pmid: 11029561].
105 U.S. Food and Drug Administration, Center for Devices and Radiological Health. Class II special controls guidance document: resorbable calcium salt bone void filler device: guidance for Industry and FDA. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health. Jun. 2. 2003:9. Also available: http://www.fda.gov/cdrh/ode/guidance/855.pdf.
106 Laurencin CT, Pratt LT, Kahn Y. Bone graft substitute materials. eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. [cited 2005 Jun 15]. 10. 1996- [updated 2005 Mar 15]. Available: http://www.emedicine.com/orthoped/topic611.htm.
107 Parikh SN. Bone graft substitutes: past, present, future. J Postgrad Med. Apr-Jun. 2002;48(2):142-148. [pmid: 12215702].
108 U.S. Food and Drug Administration, Center for Devices and Radiological Health. Guidance document for industry and CDRH staff for the preparation of investigational device exemptions and premarket approval applications for bone growth stimulator devices. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health. Mar. 18. 1998:20. Also available: http://www.fda.gov/cdrh/ode/bgsguide.html.
109 Lieberman JR, Daluiski A, Einhorn TA. Current concepts review: the role of growth factors in the repair of bone. J Bone Joint Surg Am. 2002;84:1032-1044. [pmid: 12063342].
110 Pearson OM, Lieberman DE. The aging of Wolff's 'law': ontogeny and responses to mechanical loading in cortical bone. Am J Phys Anthropol. Suppl. 2004;39:63-99. [pmid: 15605390].
111 Hadjiargyrou M, McLeod K, Ryaby JP, Rubin C. Enhancement of fracture healing by low intensity ultrasound. Clin Orthop Relat Res. Oct. 1998;(355 Suppl):S216-S229. [pmid: 9917641].
112 EBI Bone healing system. [internet]. Parsippany (NJ). EBI Medical, Inc. [cited 2005 Sep 6]. 2. Available: http://www.ebimedical.com/products/detail.cfm?p=0C.
113 Evans RD, Foltz D, Foltz K. Electrical stimulation with bone and wound healing. Clin Podiatr Med Surg. Jan. 2001;18(1):79-95. vi. [pmid: 11344981].
114 Jervey C, Friedman RJ. Electrical stimulation: current concepts and indications. Contemp Orthop. Jan. 1990;20(1):61-65. [pmid: 10148031].
115 Ryaby JT. Clinical effects of electromagnetic and electric fields on fracture healing. Clin Orthop Relat Res. Oct. 1998;(355 Suppl):S205-S215. [pmid: 9917640].
116 Ito H, Shirai Y. The efficacy of ununited tibial fracture treatment using pulsing electromagnetic fields: relation to biological activity on nonunion bone ends. J Nippon Med Sch. Apr. 2001;68(2):149-153. [pmid: 11301360].
117 Meskens MW, Stuyck JA, Feys H, Mulier JC. Treatment of nonunion using pulsed electromagnetic fields: a retrospective follow-up study. Acta Orthop Belg. 1990;56(2):483-488. [pmid: 2239195].
118 Birnbaum K, Wirtz DC, Siebert CH, Heller KD. Use of extracorporeal shock-wave therapy (ESWT) in the treatment of non-unions. A review of the literature. Arch Orthop Trauma Surg. Jul. 2002;122(6):324-330. [pmid: 12136295].
119 Wang CJ, Chen HS, Chen CE, Yang KD. Treatment of nonunions of long bone fractures with shock waves. Clin Orthop Relat Res. Jun. 2001;(387):95-101. [pmid: 11400901].
120 Vogel J, Hopf C, Eysel P, Rompe JD. Application of extracorporeal shock-waves in the treatment of pseudarthrosis of the lower extremity. Preliminary results. Arch Orthop Trauma Surg. 1997;116(8):480-483. [pmid: 9352042].
121 Haupt G. Use of extracorporeal shock waves in the treatment of pseudarthrosis, tendinopathy and other orthopedic diseases. J Urol. Jul. 1997;158(1):4-11. [pmid: 9186313].
122 Cornell CN. Osteobiologics. Bull Hosp Jt Dis. 2004;62(1-2):13-17. [pmid: 15517852].
123 Damien CJ, Parsons JR. Bone graft and bone graft substitutes: a review of current technology and applications. J Appl Biomater. Fall. 1991;2(3):187-208. [pmid: 10149083].
124 Einhorn TA. Clinical applications of recombinant human BMPs: early experience and future development. J Bone Joint Surg Am. Suppl. 2003;85-A:82-88. [pmid: 12925614].
125 Wolfe MW, Salkeld SL, Cook SD. Bone morphogenetic proteins in the treatment of non-unions and bone defects: historical perspectives and current knowledge. Univ Pa Orthop J. Spring. 1999;12:1-6. Also available: http://www.uphs.upenn.edu/ortho/oj/html/oj12sp99p1.html.
126 Adams BD, Frykman GK, Taleisnik J. Treatment of scaphoid nonunion with casting and pulsed electromagnetic fields: a study continuation. J Hand Surg [Am]. Sep. 1992;17(5):910-914.
127 Johnson EE, Urist MR. Human bone morphogenetic protein allografting for reconstruction of femoral nonunion. Clin Orthop Relat Res. Feb. 2000;(371):61-74. [pmid: 10693551].
128 Johnson EE, Urist MR, Finerman GA. Resistant nonunions and partial or complete segmental defects of long bones. Treatment with implants of a composite of human bone morphogenetic protein (BMP) and autolyzed, antigen-extracted, allogeneic (AAA) bone. Clin Orthop Relat Res. Apr. 1992;(277):229-237. [pmid: 1555346].
129 Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston (MA). Houghton Mifflin Company. 1979:405.
130 Bechtold J. (Senior Vice President, Reimbursement and Government Affairs, EBI, L.P.). Personal communication. Aug. 30. 2005:11.
131 ECRI. Electrical bone growth stimulation for the spine and lower leg [technology assessment report]. Plymouth Meeting (PA). ECRI. Oct. 1993:106.
132 Orthofix. Physio-Stim Patient Registry Summary. McKinney (TX). Orthofix, Inc. 1.
133 Fellows R. (Vice President, Government Affairs & National Accounts, Orthofix). Personal communication. Sep. 1. 2005:3.
134 Krempen J, Silver R. External electromagnetic fields in the treatment of nonunion bones. Orthop Rev. 1981;10:33.
135 Heckman JD, Ingram AJ, Loyd RD, Luck JV Jr, Mayer PW. Nonunion treatment with pulsed electromagnetic fields. Clin Orthop Relat Res. Nov-Dec. 1981;(161):58-66. [pmid: 6975692].
136 Bassett CA, Mitchell SN, Gaston SR. Pulsing electromagnetic field treatment in ununited fractures and failed arthrodeses. JAMA. Feb. 5. 1982;247(5):623-628. [pmid: 7054564].
137 Sharrard WJ, Sutcliffe ML, Robson MJ, Maceachern AG. The treatment of fibrous non-union of fractures by pulsing electromagnetic stimulation. J Bone Joint Surg Br. 1982;64(2):189-193. [pmid: 6978339].
138 Marcer M, Musatti G, Bassett CA. Results of pulsed electromagnetic fields (PEMFs) in ununited fractures after external skeletal fixation. Clin Orthop Relat Res. 1984;190:260-265. [pmid: 6488642].
139 Dunn AW, Rush GA 3d. Electrical stimulation in treatment of delayed union and nonunion of fractures and osteotomies. South Med J. Dec. 1984;77(12):1530-1534. [pmid: 6390697].
140 Cheng N, Van Hoof H, Delport PH, Hoogmartens MJ, Mulier JC. Treatment of non-union, congenital pseudarthroses and benign cystic lesions using pulsed electromagnetic fields. Reconstr Surg Traumatol. 1985;19:118-122. [pmid: 3873095].
141 Hinsenkamp M, Ryaby J, Burny F. Treatment of non-union by pulsing electromagnetic field: European multicenter study of 308 cases. Reconstr Surg Traumatol. 1985;19:147-151. [pmid: 3887518].
142 Frykman GK, Taleisnik J, Peters G, Kaufman R, Helal B, Wood VE, Unsell RS. Treatment of nonunited scaphoid fractures by pulsed electromagnetic field and cast. J Hand Surg [Am]. May. 1986;11(3):344-349.
143 Colson DJ, Browett JP, Fiddian NJ, Watson B. Treatment of delayed- and non-union of fractures using pulsed electromagnetic fields. J Biomed Eng. Jul. 1988;10(4):301-304. [pmid: 3266275].
144 Jimenez ML, Anderson TL. The use of allograft, platelet-derived growth factors, and internal bone stimulation for treatment of recalcitrant nonunions [poster no. 52]. Hippocrates Winslow & Babbage Foundation 2003 Annual Meeting. February 6, 2003. New Orleans (LA). 2003. Also available: http://www.hwbf.org/ota/am/ota03/otapo/OTP03052.htm.
145 Forsted DL, Dalinka MK, Mitchell E, Brighton CT, Alavi A. Radiologic evaluation of the treatment of nonunion of fractures by electrical stimulation. Radiology. Sep. 1978;128(3):629-634. [pmid: 307776].
146 Paterson DC, Lewis GN, Cass CA. Treatment of delayed union and nonunion with an implanted direct current stimulator. Clin Orthop Relat Res. May. 1980;(148):117-128. [pmid: 6991188].
147 Zichner L. Repair of nonunions by electrically pulsed current stimulation. Clin Orthop Relat Res. Nov-Dec. 1981;(161):115-121. [pmid: 6975687].
148 Connolly JF. Selection, evaluation and indications for electrical stimulation of ununited fractures. Clin Orthop Relat Res. Nov-Dec. 1981;(161):39-53. [pmid: 6975690].
149 Ahl T, Andersson G, Herberts P, Kalen R. Electrical treatment of non-united fractures. Acta Orthop Scand. Dec. 1984;55(6):585-588. [pmid: 6335345].
150 Yuan ZX, Tang YG, Lu XY, Yu HL, Zhao DZ. Continuous direct current in the treatment of nonunion and delayed union. Chin Med J (Engl). Feb. 1986;99(2):133-138. [pmid: 3093161].
151 Schaden W, Fischer AJ, Sailler A, Karadas E. Extracorporeal shockwave therapy (ESWT) for tibia non-unions [paper no. 355]. American Academy of Orthopaedic Surgeons 2005 Annual Meeting. February 23-27, 2005. Washington (DC). 2005. Also available: http://www.aaos.org/wordhtml/anmt2005/sciprog/395.htm.
152 Koval KJ. (Professor, Dartmouth Hitchcock Medical Center). Personal communication. Aug. 22. 2005:5.
153 Miller R, Mont MA. Clinical experience with osteogenic protein-1 for the treatment of recalcitrant long bone nonunions [poster board number: P395]. American Academy of Orthopaedic Surgeons 2005 Annual Meeting. February 23-27, 2005. Washington (DC). 2005. Also available: http://www.aaos.org/wordhtml/anmt2005/poster/p395.htm.
154 Office of Device Evaluation, Center for Devices and Radiological Health (CDRH). Premarket approval application notification. H010002. Stryker Biotech, OP-1 Implant. Oct. 17. 2001:8.
155 Wyeth Pharmaceuticals. New device approval: Wyeth Pharmaceuticals INFUSE bone graft - P000054. [internet]. Rockville (MD). Office of Device Evaluation, Center for Devices and Radiological Health (CDRH). Apr. 130. [cited 2005 Jun 7]. 2004:3. Available: http://www.fda.gov/cdrh/mda/docs/p000054.html.
156 Orozco L, Rodriguez L, Torrico C, Douville J, Hock JM, Armstrong RD, Garcia J, Solano C. Clinical feasibility study: the use of cultured enriched autologous bone marrow cells to treat refractory atrophic and hypotrophic nonunion fractures. Ann Arbor (MI). Aastrom Biosciences, Inc. May. 12. 2005:19.
157 Yoffee Aastrom Biosciences. Drug development; Bone graft trial expanded to include New York Hospital. NewsRx.com [internet]. Atlanta (GA). Medical Devices & Surgical Technology Week, NewsRX.com. Apr. 3. [cited 2005 Jun 17]. 2005:155. Available: http://www.newsrx.com/cgi-bin/single_article_search.cgi.
158 McKee MD, Wild LM, Schemitsch EH, Waddell JP. The use of an antibiotic-impregnated, osteoconductive, bioabsorbable bone substitute in the treatment of infected long bone defects: early results of a prospective trial. J Orthop Trauma. 2002;16(9):622-627. [pmid: 12368641].
159 Wilkins RM, Kelly CM, Giusti DE. Bioassayed demineralized bone matrix and calcium sulfate: use in bone-grafting procedures. Ann Chir Gynaecol. 1999;88(3):180-185. [pmid: 10532559].
160 Luchetti R. Corrective osteotomy of malunited distal radius fractures using carbonated hydroxyapatite as an alternative to autogenous bone grafting. J Hand Surg [Am]. Sep. 2004;29(5):825-834.
161 Office of Device Evaluation, Center for Devices and Radiological Health (CDRH). Premarket approval application notification. P900009/S6. Exogen 2000 or Sonic Accelerated Fracture Healing system (SAFHS). Feb. 22. 2000:6.
162 Exogen. Exogen 2000 summary of safety and effectiveness. P900009. Piscataway (NJ). Exogen. Feb. 22. 2000:19. Also available: http://www.fda.gov.
163 Exogen. SAFHS 2000 (sonic accelerated healing system for the treatment of nonunion: physician's instructions for use. Piscataway (NJ). Exogen, Inc. Jun. 18. 1998:45. Also available: http://www.fda.gov.
164 Pigozzi F, Moneta MR, Giombini A, Giannini S, Di Cesare A, Fagnani F, Mariani PP. Low-intensity pulsed ultrasound in the conservative treatment of pseudoarthrosis. J Sports Med Phys Fitness. Jun. 2004;44(2):173-178. [pmid: 15470315].
165 Lerner A, Stein H, Soudry M. Compound high-energy limb fractures with delayed union: our experience with adjuvant ultrasound stimulation (exogen). Ultrasonics. Apr. 2004;42(1-9):915-917. [pmid: 15047406].
166 Jones NF, Brown EE, Mostofi A, Vogelin E, Urist MR. Healing of a scaphoid nonunion using human bone morphogenetic protein. J Hand Surg [Am]. May. 2005;30(3):528-533.
167 Delloye C, Suratwala SJ, Cornu O, Lee FY. Treatment of allograft nonunions with recombinant human bone morphogenetic proteins (rhBMP). Acta Orthop Belg. Dec. 2004;70(6):591-597. [pmid: 15669462].
168 Saltzman C, Lightfoot A, Amendola A. PEMF as treatment for delayed healing of foot and ankle arthrodesis. Foot Ankle Int. Nov. 2004;25(11):771-773. [pmid: 15574233].
169 Nishikawa S, Toh S, Tsukahara S, Takahashi I. Endoscopic treatment of delayed unions and nonunions with calcium phosphate paste. Arthroscopy. Apr. 2003;19(4):436-439. [pmid: 12671628].
170 Kloen P, Doty SB, Gordon E, Rubel IF, Goumans MJ, Helfet DL. Expression and activation of the BMP-signaling components in human fracture nonunions. J Bone Joint Surg Am. Nov. 2002;84-A(11):1909-1918. [pmid: 12429748].
171 Ikeda K, Tomita K, Takayama K. Application of extracorporeal shock wave on bone: preliminary report. J Trauma. Nov. 1999;47(5):946-950. [pmid: 10568728].
172 Rosenthal RK, Folkman J, Glowacki J. Demineralized bone implants for nonunion fractures, bone cysts, and fibrous lesions. Clin Orthop Relat Res. Jul. 1999;(364):61-69. [pmid: 10416393].
173 Satter Syed A, Islam MS, Rabbani KS, Talukder MS. Pulsed electromagnetic fields for the treatment of bone fractures. Bangladesh Med Res Counc Bull. Apr. 1999;25(1):6-10. [pmid: 10758655].
174 Abeed RI, Naseer M, Abel EW. Capacitively coupled electrical stimulation treatment: results from patients with failed long bone fracture unions. J Orthop Trauma. Sep-Oct. 1998;12(7):510-513. [pmid: 9781776].
175 Frankel VH. Results of prescription use of pulse ultrasound therapy in fracture management. Surg Technol Int. 1998;VII:38993.
176 Bai MH, Liu XY, GE BF, Yallg C, Chen DA. An implant of a composite of bovine bone morphogenetic protein and plaster of paris for treatment of femoral shaft nonunions. Int Surg. Oct-Dec. 1996;81(4):390-392. [pmid: 9127802].
177 Holmes GB Jr. Treatment of delayed unions and nonunions of the proximal fifth metatarsal with pulsed electromagnetic fields. Foot Ankle Int. Oct. 1994;15(10):552-556. [pmid: 7834063].
178 Schleberger R, Senge T. Non-invasive treatment of long-bone pseudarthrosis by shock waves (ESWL). Arch Orthop Trauma Surg. 1992;111(4):224-227. [pmid: 1622713].
179 Sharrard J. [D-1-3] A double-blind trial of PEMFS for delayed tibial union - clinical follow-up. 16th Annual Meeting of the Bioelectromagnetical Society. 1994. Copenhagen, Denmark. 1994.