# METHODS

## Key Questions Addressed

In order to meet the objectives of this report, we address the following Key Questions:

1. Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for diagnostic catheterization procedures?
2. Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for interventional catheterization procedures?
3. Do hospitals without cardiac surgical support and hospitals with cardiac surgical support have comparable complication rates for diagnostic and interventional catheterization procedures? This question will only be addressed if the literature is insufficient for Questions 1 and/or 2 for freestanding clinics.
4. What are the characteristics of patients who have had catheterization procedures in freestanding cardiac catheterization clinics vs. hospitals?
5. What are the current state regulations, Certificate of Need (CON) requirements, and oversight procedures for freestanding cardiac catheterization clinics?

In assessing safety, we consider all reported complications that may be related to the catheterization procedure.

## Literature Searches

Details of our literature searches, which included searches of 12 electronic databases, hand searches of the bibliographies of all retrieved articles, and searches of the gray literature, are presented in Appendix A.

## Inclusion/Exclusion Criteria

We used the following general criteria to determine which studies would be included in our analysis for Key Questions 1 through 4:

1. Studies must have been published in English.
2. Studies must have addressed one of the Key Questions.
3. Studies must have included at least 100 patients per arm. This is to ensure that adverse events that occur in at least 1% of patients are detectable (Questions 13) and to ensure a representative sampling of patients (Questions 1–4). Although event rates below 1% may also be of interest, we chose a less conservative criterion to allow inclusion of more studies.
4. Full published studies and relevant meeting abstracts will be included.
5. If the same study is reported in multiple publications, only the most recent publication will be included. This serves to avoid duplication of data.

Additional criteria specific to individual questions are presented in the Results section under each Key Question.

## Data Extraction

Information extracted from the included studies is presented in Evidence Tables in Appendix E. These tables describe study results, design details (prospective, blinding status, etc.), information on enrolled patients (demographics, underlying etiology, etc.), and information on the setting of the study (freestanding or hospital, hospital with or without surgical support).

We have only extracted outcome data relevant to the Key Questions in this report. If relevant data were reported in figures but not in text, we estimated them from the figures. When study authors did not report dichotomous data as percentages, we computed percentages.

## Evaluation of the Quality of the Evidence Base

We rated evidence strength and internal validity using standard criteria as proposed by the U.S. Preventive Services Task Force (USPSTF). The first step in this process involves identifying the study design and labeling it according to the hierarchy shown in Table 1.(20

Table 1 Hierarchy of Research Design (USPSTF)

Level | Definition
I | Evidence obtained from at least one properly randomized controlled trial.
II-1 | Evidence obtained from well-designed controlled trials without randomization.
II-2 | Evidence obtained from well-designed cohort or case-control analytic studies, preferably from more than one center or research group.
II-3 | Evidence obtained from multiple time series with or without the intervention. Dramatic results in uncontrolled experiments (e.g., penicillin) also qualify.
III | Opinions of respected authorities, based on clinical experience, descriptive studies and case reports, or reports of expert committees.

In recent years USPSTF has recognized that this hierarchy by itself gives inadequate consideration of internal validity (how well a study was conducted). For example, a well-designed cohort study may be of higher quality than a poorly-conducted randomized controlled trial. Therefore, they adopted an additional system for ranking internal validity (“good”"fair”, or “poor”). A “good” rating means that a study meets all criteria for that particular study design, a “fair” study does not meet all criteria but is judged to have no fatal flaw that invalidates its results, and a “poor” study contains a fatal flaw.(20) We have added an additional category called “low”, which describes a study that is borderline acceptable (not quite “fair”, but not necessarily fatally flawed). For more information on the criteria used to rate studies, see the Quality of Included Studies section under each Key Question in the Evidence Synthesis section of the report.

We estimated the generalizability of each study to the U.S. Medicare population using study enrollment criteria and the reported characteristics of the patients who were actually enrolled in the study.