# EVIDENCE SYNTHESIS

Because each Key Question had a different evidence base, we describe each evidence base separately under the relevant Key Question.

## Key Question 1 Do Freestanding Cardiac Catheterization Clinics and Hospitals Have Comparable Complication Rates for Diagnostic Catheterization Procedures?

### Question-Specific Inclusion/Exclusion Criteria

In addition to the general inclusion/exclusion criteria listed under Methods, the following additional criteria were used to select studies for this question:

1. Studies must be controlled studies that compare data from freestanding clinics to parallel or historical control groups in outpatient hospital settings. If no controlled studies are available, outpatient case series will be included for indirect comparison of freestanding clinics and hospitals.
2. Studies must include data related to the Key Outcomes.
3. Studies must provide a quantitative description of findings (e.g., numbers or percentages).

### Evidence Base

Our searches found no controlled trials that addressed this question, so we searched for lower level evidence (uncontrolled case series from freestanding clinic or hospital outpatient settings). We identified 27 articles that potentially met our a priori inclusion criteria and were therefore retrieved. On retrieval, four of the 27 articles were found not to meet our inclusion criteria. The reasons for exclusion were either that inpatient and outpatient data were not reported separately (two articles) or that no quantitative statement (number or percentage) of complications was reported. These articles and the reason for their exclusion are listed in Table B-1 of Appendix B.

Having excluded the four articles above, 23 studies remained. These studies, which are listed in Table 2, consist of one randomized controlled trial (RCT) and 22 case series. The RCT randomized patients to receive diagnostic catheterization on an inpatient or outpatient basis in a hospital setting. For the purposes of this question, only the outpatient group in the RCT was relevant, so only the outpatient data were included (effectively making it equivalent to the other case series). Details of these studies are presented in Table C-1 to C-3, Appendix C.

Table 2 Evidence Base for Key Question 1

Study Design | References
Randomized Controlled Trials | Block et al.(21)
Case series | Akdemir et al.(22); Peterson and Peterson(23); Bersin et al.(24); Elliott et al.(25); Clark and Dolce(26); Clements and Gatlin(27); Kern et al.(28); Jackson(27); Murray and Rothman(29); Oldroyd et al.(30); Pink et al.(31); Murdock et al.(32); Mahrer et al.(33); Fighali et al.(34); Klinke et al.(35); Fierens(36); Diethrich et al.(37); Mahrer and Eshoo(38); Gavin et al.(39); Oehlert(40); Perrigo et al.(41); Baird(42)

### Quality of Included Studies

None of the included studies compared the complication rates of diagnostic catheterization in freestanding clinics and hospitals, so no direct comparisons are possible in this technology assessment. The only published data on complications in freestanding clinics appear in case series. For the purpose of informal indirect comparison, we have also included case series reporting complication rates of diagnostic catheterization in hospital outpatient settings.

We have not included case series that reported complication rates among hospital inpatients or in a mixed series of inpatients and outpatients, because sicker patients are included among the inpatients. Thus, inpatients will be more likely to experience procedure-related complications, which would bias any comparison with a group of lower-risk patients diagnosed in a freestanding setting. By contrast, outpatient series will include mostly low-risk patients who are more comparable to the low-risk patients who would be diagnosed in freestanding clinics. However, even this comparison is imperfect, because risk levels may differ somewhat even among different outpatient settings. For example, some evidence suggests that community hospitals are more likely to receive somewhat higher risk patients among their outpatient population than physician-owned specialty hospitals. Similarly, hospital outpatient departments in general may be more likely to receive higher risk patients than ambulatory surgical centers or physician offices for the same outpatient procedures.(43)

Despite our attempts to select the most comparable studies, indirect comparisons are inherently problematic. Patient populations in case series performed at different institutions will never be completely identical, and these studies may contain additional differences that undermine cross-study comparisons. Although differences in patient characteristics can be adjusted for statistically in some circumstances, this was not possible in the current evidence base due to the lack of individual patient data. Thus, if differences in adverse event rates appear when comparing freestanding and hospital outpatient series, one can never be certain that the differences can be explained solely by the difference in setting. Nevertheless, this is the best comparison possible given the available literature.

A related issue of some concern is the possibility that this evidence base could be affected by publication bias. If some freestanding clinics have not published data because of substandard outcomes, then the published results of freestanding clinics will appear to be better than they would have appeared had results from all clinics been published. The low number of freestanding clinic studies (only five were identified) precludes determination of whether or to what extent this literature may have been affected by publication bias. However, the potential for bias exists and must be considered when interpreting the results.

Finally, differences in follow-up time might lead to differences in complication rates among studies. All of the studies in freestanding clinics and some of the hospital outpatient studies did not report the length of followup. Most complications of diagnostic catheterization occur within the first 24 hours, and most studies probably reported data from within this time period at least. However, a few hospital outpatient studies reported complications for up to one week or even four weeks, and what percentage of additional complications may occur during this extended period is unknown, as the studies did not report the time at which complications occurred.

According to USPSTF criteria, all studies in this evidence base are Level III studies, which are generally considered to be of low quality (because only one arm of the RCT by Block et al. could be used, this study had to be evaluated as a case series for this question). Because none of the studies contains a direct, within-study comparison of complications in freestanding settings and hospital outpatient facilities, the quality of all of the individual studies (and hence the evidence base) is low.

### Details of Study Enrollees and Study Generalizability

None of the study populations were completely generalizable to the Medicare population. All of the studies that reported age had some overlap with the Medicare population, but the age ranges were generally large, ranging from adolescent or young adult to elderly. Furthermore, females tended to be underrepresented in these studies relative to the Medicare population. Finally, not all studies reported age or gender information. Therefore, the generalizability of the studies to the Medicare population is “Fair.”^2^ Details of the patients enrolled in these studies are presented in Table C-2 and Table C-3 of Appendix C.

2 High = Characteristics of all enrolled patients typical of Medicare population; Fair = Characteristics of some enrolled patients typical of Medicare population; Poor = Characteristics of only a few enrolled patients typical of Medicare population or enrolled patients represent a subgroup of Medicare population.

Another noteworthy issue is that the majority of studies in the evidence base were published in the 1980s. Therefore, they may only have limited relevance to current clinical practice in the indicated settings. However, complication rates generally tend to decrease over time due to increasing practitioner experience and improvements in technology.

### Findings of Included studies

#### Studies in Freestanding Laboratories

Five separate studies with a total of 18,082 patients reported data concerning complication rates of diagnostic catheterization in freestanding settings. All were published in the 1980s. Two consisted of data from registries that were reported as part of a systematic review of the topic, but not otherwise published.(12) The remaining three were single-laboratory case series, one of which was published as a meeting abstract.

The mortality rates in these studies ranged from 0 to 0.16%, as did the rate of MI, while the rate of stroke/transient ischemic attack (TIA) ranged from 0 to 0.03%. Vascular complications ranged from 0 to 2.0%. Other complications were inconsistently reported across studies (see Table C-4, Appendix C for specific complication rates for each study).

#### Studies in Hospital Outpatient Laboratories (Mobile or Fixed)

Nineteen studies reported complication rates of diagnostic catheterization in this setting. Twelve of these were published in the 1980s, with the remaining seven published more recently.

Three of the most recent studies reported complications in mobile laboratories which serviced hospitals that lacked catheterization labs. There were no reported deaths out of a total of 4,261 patients in these three studies. Rates of MI ranged from 0 to 0.3%, rates of stroke/TIA ranged from 0 to 0.1%, and rates of vascular complications ranged from 0 to 0.1%.

The remaining 16 studies reported complication rates for a total of 20,129 patients in fixed hospital outpatient laboratories. Mortality rates ranged from 0 to 0.3%, MI rates ranged from 0 to 0.7%, rates of stroke/TIA ranged from 0 to 0.4%, and vascular complications ranged from 0 to 2.0%. Among the less serious complications, the most frequent was bleeding/hematoma, with rates ranging from 0 to 7% (see Table C-4, Appendix C for specific complication rates for each study).

These complication rates do not differ substantially from the rates reported in the largest study of diagnostic catheterization complications, a multicenter registry study of 222,553 patients who received coronary arteriography between 1984 and 1987.(44) This study did not meet our inclusion criteria because it did not report findings separately for inpatients and outpatients. However, we note that the average rates reported by this study for mortality (0.1%), MI (0.06%), stroke/TIA (0.07%), and vascular complications (0.46%) all fall within the ranges reported by the studies that met our inclusion criteria.

### Subsection Summary

After searching the literature, retrieving references, and applying our inclusion/exclusion criteria, we identified 23 publications that reported complication rates of diagnostic catheterization procedures in a freestanding or hospital outpatient setting. None of these studies directly compared complication rates in freestanding and hospital settings. Thus, the quality of the evidence is low. The studies’ generalizability to the Medicare population was fair.

Five studies reported complications in a freestanding laboratory (two of these studies were reported only in a systematic review). The mortality rate ranged from 0 to 0.16% and equal or lower rates were found for MI and stroke. No deaths occurred in any of the three mobile laboratory studies, while the mortality rate ranged from 0 to 0.3% among the 16 fixed hospital outpatient studies. Rates of MI, stroke/TIA, and vascular complications were similar or slightly higher than those reported in freestanding settings (see Table 3).

Table 3 Range in Complication Rates in Different Care Settings

Care setting | Number of studies | Mortality rate (range) | MI rate (range) | Stroke rate (range) | Vascular complications (range)
Freestanding clinic | 5 | 0 to 0.16% | 0 to 0.16% | 0 to 0.03% | 0 to 2.0%
Hospital outpatient (mobile) | 3 | 0 to 0% | 0 to 0.1% | 0 to 0.3% | 0 to 0.1%
Hospital outpatient (fixed) | 16 | 0 to 0.3% | 0 to 0.7% | 0 to 0.4% | 0 to 2.0%

The available evidence did not reveal substantial differences in complication rates of diagnostic catheterization procedures among freestanding and hospital outpatient settings. However, this indirect and informal comparison of low quality studies could not be risk-adjusted to compensate for differences in patient characteristics among the studies. Also, none of the freestanding studies reported the length of followup; if it was shorter than the average followup in the hospital outpatient studies, this would create bias in the comparison. Furthermore, we cannot determine whether the relatively low complication rates reported in freestanding studies are generalizable to all freestanding centers, as this evidence base was susceptible to potential publication bias. These flaws in the evidence base mean that we cannot completely rule out the possibility of differences in complication rates between these settings.

## Key Question 2 Do Freestanding Cardiac Catheterization Clinics and Hospitals Have Comparable Complication Rates for Interventional Catheterization Procedures?

### Question-Specific Inclusion/Exclusion Criteria

In addition to the general inclusion/exclusion criteria listed under Methods, the following additional criteria were used to select studies for this question:

1. Studies must be controlled studies that compare data from freestanding clinics to parallel or historical control groups in outpatient hospital settings. If no controlled studies are available, outpatient case series will be included for indirect comparison of freestanding clinics and hospitals.
2. Studies must include data related to the Key Outcomes.
3. Studies must provide a quantitative description of findings.

### Evidence Base

Our searches identified no articles or meeting abstracts that potentially met our a priori inclusion criteria. Thus, no evidence-based conclusion is possible for this question. An ACC/SCAI consensus document recommended that such procedures not be performed in freestanding settings, and we found no information to suggest that PCI procedures are currently being performed in this setting.

## Key Question 3 Do Hospitals without Cardiac Surgical Support and Hospitals with Cardiac Surgical Support have Comparable Complication Rates for Interventional Catheterization Procedures?

We address this question because Key Question 2 could not be answered in an evidence-based fashion. However, hospitals without cardiac surgical support are an imperfect surrogate for freestanding clinics, because even hospitals without cardiac surgical support have support services and resources beyond what is typically found in freestanding settings. Therefore, one cannot be certain to what extent, if any, the findings for interventional procedures in a hospital setting can be extrapolated to a freestanding setting.

### Question-Specific Inclusion/Exclusion Criteria

In addition to the general inclusion/exclusion criteria listed under Methods, the following additional criteria were used to select studies for this question:

1. Studies must be controlled studies that compare data from hospitals with and without cardiac surgical support. If no controlled studies are available, case series will be included for indirect comparison of hospitals with and without cardiac surgical support.
2. Studies must include data related to the Key Outcomes.
3. Studies must provide a quantitative description of findings.

### Evidence Base

Our searches identified 14 articles or meeting abstracts that potentially met our a priori inclusion criteria and were therefore retrieved. Because controlled trials were available, we did not retrieve case series. On retrieval, seven of the 14 articles were found not to meet our inclusion criteria. The primary reasons for exclusion (four articles) were that the studies combined data from several procedures (PCI, CABG, thrombolytic therapy) and did not separately report the data for patients who received PCI. The remaining three articles were excluded for a variety of other reasons. These latter articles and the reason for their exclusion are listed in Table B-1 of Appendix B.

Having excluded the seven articles above, five articles and two meeting abstracts remained. These studies, which are listed in Table 4 are all non-randomized retrospective cohort studies. Details of these studies are presented in Table D-1 to D-6, Appendix D.

Table 4 Evidence Base for Key Question 3

Study Design | References
Non-Randomized Retrospective Controlled Studies | Kutcher et al.(45); Sanborn et al.(46,47); Singh et al.(48); Wennberg et al.(49); Wharton et al.(50); Weaver et al.(51); Garratt et al.(52)

### Quality of Included Studies

Seven studies that enrolled a total of 933,477 individuals compared PCI-related complication rates in hospitals with and without cardiac surgical support.(46, 48–52) The results of our analysis of the quality of these studies are summarized in Table 5. We based the quality ratings for each study (shown in Table 3) on the criteria and information presented in Table D-1 of Appendix D. The difference between a judgment of “fair” or “low” generally depended upon whether the study authors performed any type of risk-adjustment in their comparisons of different patient groups.

Table 5 Quality of Studies Comparing Interventional Catheterization Procedures in Hospitals With and Without Cardiac Surgical Support

Reference | Year | Study Design | USPSTF Quality Rating^a^
Sanborn et al.(46,47) | 2004 | Non-Randomized Retrospective Controlled Study | Level II-3-Low
Singh et al.(48) | 2004 | Non-Randomized Retrospective Matched Controlled Study | Level-II-3-Fair
Wennberg et al.(49) | 2004 | Non-Randomized Retrospective Controlled Study | Level II-3-Fair
Wharton et al.(50) | 1999 | Non-Randomized Retrospective Controlled Study | Level II-3-Low
Weaver et al.(51) | 1995 | Non-Randomized Retrospective Controlled Study | Level II-3-Fair
Kutcher et al.(45) (abstract) | 2004 | Non-Randomized Retrospective Controlled Study | Level II-3-Low
Garratt et al.(52) (abstract) | 2002 | Non-Randomized Retrospective Controlled Study | Level II-3-Fair

a See criteria proposed by the U.S. Preventive Services Task Force.(20)

### Details of Study Enrollees and Study Generalizability

Details about the patients enrolled in these studies are presented in Table D-3 to D-6 of Appendix D. Only the study by Wennberg et al., which focused exclusively on Medicare enrollees, was found to be highly generalizable to the elderly Medicare population.(49) The remaining six studies included some adults under age 65, and women tended to be underrepresented (they were 21% to 35% of the population in each study) relative to the Medicare population. Therefore, the generalizability of these latter studies was considered to be “Fair.”^3^

3 High = Characteristics of all enrolled patients typical of Medicare population; Fair = Characteristics of some enrolled patients typical of Medicare population; Poor = Characteristics of only a few enrolled patients typical of Medicare population or enrolled patients represent a subgroup of Medicare population.

### Findings of Included Studies

We present separate findings based on two categories of PCI reported in the literature: non-primary and primary PCI. Our definition of these terms is based on the definitions provided in the study by Wennberg et al.(49) Accordingly, in this document, non-primary PCI refers to all PCI procedures performed for reasons other than an emergency admission for acute MI. Conversely, primary PCI refers to all PCI procedures performed for emergency admission for acute MI. We recognize the fact that the terminology is somewhat inconsistent in the literature. We do not include all cases of rescue PCI (PCI used after failed thrombolysis) in the category of non-primary PCI, as rescue PCI may be performed in patients with or without emergent acute MI. The only study that reported cases of rescue PCI (Wennberg et al.) divided these cases into the separate groups of non-primary and primary PCI.(49)

#### Non-Primary PCI

Three included studies compared complication rates among patients receiving non-primary PCI in hospitals with and without surgical support (results appear in Table D-7, Appendix D). Although none of these patients had emergent acute MI, non-primary PCI may still include patients who had an emergency admission for other reasons (e.g., unstable angina). Because none of the studies were randomized, all were vulnerable to selection bias that could have confounded the comparisons. Another potential weakness in these studies is that, with one exception, they did not state whether they accounted for patients who arrived at the study hospitals but were transferred to another facility for treatment. Sanborn et al. was the only study that mentioned this problem, and they acknowledged that they did not track the mortality status of transfer patients.(46) Not accounting for such patients could have biased the comparison.

Garratt et al. conducted the only controlled study that exclusively evaluated patients who received elective PCI procedures.(52) Because freestanding clinics generally perform elective diagnostic procedures, the patient population receiving treatment in the Garratt et al. study may be the most relevant to a freestanding setting. This study found similar death rates for elective PCI at two hospitals, one with cardiac surgical support (0.72%) and one without (0.49%).(52) However, this study was not large enough to detect small differences in mortality rates.

The remaining two studies compared all non-primary PCI procedures at hospitals with and without surgical support. Wennberg et al. conducted a large retrospective study of Medicare enrollees who had received PCI. Of patients who received non-primary PCI, most were at hospitals with cardiac surgery support (583,149 vs. 6,373 at hospitals without surgical support). Some patients in this group received rescue PCI for causes other than emergent acute MI. They found a significantly higher mortality rate at hospitals without cardiac surgery support (4.6% vs. 2.8%, p <0.001). The adjusted odds ratio (adjusted for age, sex, race, year, comorbidity score, primary diagnosis, acuity, multivessel PCI, and stent use) was also statistically significant (1.38, 95% CI 1.14 to 1.67, p = 0.001).(49) The authors performed a number of further subgroup analyses that suggested that the excess mortality at hospitals without cardiac surgical backup was higher among emergent patients and at low volume institutions. Because hospitals without surgical backup received more emergent patients and were much more likely to be low volume institutions than hospitals with surgical backup, the difference in mortality rates could be potentially accounted for by a combination of these factors rather than the lack of surgical backup. However, subgroup analyses are potentially misleading, as the findings of such analyses may occur by chance. At best, they can only generate hypotheses that may be further tested in future studies.

Kutcher et al. made a similar comparison of PCI procedures reported in the ACC-NCDR database. Again, the majority of patients received PCI at hospitals with cardiac surgical support (198,555 vs. 1,668 at hospitals without surgical support). Despite the large number of patients, this study did not find a statistically significant difference in death rates between the two settings (0.54% without support vs. 0.46% with support, p = 0.79).(45) Because this study made no risk adjustments to account for between-group patient differences, it was more vulnerable to bias than the other two studies.

#### Primary PCI

Six of the seven included studies compared complication rates in patients with acute MI receiving primary PCI in hospitals with and without cardiac surgical support (see Table D-8, Appendix D). All of these patients had suffered an acute MI. As stated earlier, patients with acute MI are likely to be sent to a hospital’s emergency department, so this subgroup of patients may be different than patients who would undergo non-emergency procedures in a freestanding setting.

Using data from the National Registry of Myocardial Infarction (NRMI), Sanborn et al. compared patients in three different hospital settings (diagnostic catheterization only, PCI only, and PCI with surgical support ) and found no significant difference in rates of mortality (3.2%, 4.2%, 4.8%, p = 0.07), stroke (0.6%, 0.4%, 0.7%, p = 0.44), or recurrent AMI (0.6%, 1.5%, 1.2%, p = 0.19).(46) However, they did not attempt to adjust for differences in patient characteristics, and they acknowledged that they did not track the mortality status of patients transferred out of hospitals without cardiac surgical support. These factors could have confounded the comparisons.

Singh et al. compared patients receiving PCI after AMI in two hospitals, one without and one with cardiac surgery backup. Patients were matched according to age, procedure date, ST-segment elevation MI, anterior site of infarction, presentation with congestive heart failure, and a propensity score based on numerous risk factors. No statistically significant between-hospital difference was observed for mortality (1.9% vs 1.3%, p = 0.56), need for CABG (0.6% vs 0.6%), or reinfarction rates (0.6% vs 0%, p = 0.32).(48)

Wennberg et al.’s study of Medicare enrollees also compared patients who received PCI following emergent admission for MI at hospitals without or with surgical backup. Some of these patients received rescue PCI for failed thrombolysis. They found no statistically significant between-setting differences in mortality rates (11.3% vs 12.2%, p = 0.24)) or need for CABG (4.6% vs 5.1%, p = 0.29), even after risk-adjustment (for age, sex, race, year, comorbidity score, primary diagnosis of acute MI, acuity, multivessel PCI, and stent use).(49)

Wharton et al. conducted a study of primary angioplasty at two hospitals that did not offer surgical support.(50) Although this was technically an uncontrolled study, they compared a subgroup of patients (all patients with ST-segment elevation MI) to a similar group of patients described in the Primary Angioplasty Registry (a registry of hospitals with cardiac surgical backup).(53) They found no statistically significant between-group differences in mortality (3.9% vs 4.0%, p = 0.82), stroke (0.4% vs 1.0%, p = 1.0), or reinfarction rates (3% vs 3%). The authors did not make risk adjustments to account for potential differences between the two populations.

Weaver et al. compared post-PCI outcomes after MI at several hospitals with and without cardiac surgical backup that participated in the Myocardial Infarction Triage and Intervention (MITI) registry. They found no statistically significant between-setting difference in rates of mortality (7% for each) or need for CABG by discharge (8.5% vs 12%, p = 0.07). However, patients at hospitals with cardiac surgical support had a significantly greater chance of undergoing CABG within six hours (p <0.01) or 24 hours (p <0.03) of admission. The authors also performed a multivariable analysis of 30 day mortality, adjusting for baseline differences, and found no significant difference between hospital settings.(51)

Finally, Kutcher et al. compared PCI results in settings with or without surgical support separately for patients with Non-ST MI and ST elevation MI. In both cases they found no statistically significant difference between settings for mortality or need for emergency surgery.(45) However, they did not adjust for baseline differences among patients in different care settings.

### Subsection Summary

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified seven retrospective controlled studies (five articles and two meeting abstracts) that compared complication rates of non-primary or primary PCI in hospitals with or without cardiac surgical support. These studies ranged from low to fair in quality based on USPSTF ratings. All were vulnerable to potential selection bias from lack of randomization and lack of followup of patients transferred to other hospitals. Generalizability to the Medicare population was fair except for one study where it was high.

Three studies of non-primary PCI (PCI for reasons other than emergent acute MI) reported conflicting results. One of these studies exclusively evaluated elective PCI procedures and found no statistically significant differences in complication rates between care settings. The remaining two studies evaluated all non-primary PCI procedures (including some emergent procedures). The only study that exclusively evaluated Medicare patients showed a significantly higher mortality rate in hospitals without cardiac surgical support, while the remaining study showed no significant difference between care settings. However, the latter study was of low quality because no adjustments were made to account for baseline between-group differences in patient characteristics. Because these studies were vulnerable to selection bias and differed from each other in several characteristics, the conflicting results cannot be explained with certainty.

Three of the six available studies of primary PCI adjusted for differences in patient risk and three did not. None of them found a statistically significant difference in rates of mortality or serious morbidity between hospitals with and without cardiac surgical backup. However, the low to fair quality of these studies means that failure to demonstrate a difference does not eliminate the possibility that a difference may exist.

## Key Question 4 What Are the Characteristics of Patients Who Have Had Catheterization Procedures in Freestanding Cardiac Catheterization Clinics vs. Hospitals?

### Question-Specific Inclusion/Exclusion Criteria

In addition to the general inclusion/exclusion criteria listed under Methods, the following additional criteria were used to select studies for this question:

1. Studies of any design that met the general criteria were acceptable, provided that they contained information on prognostic factors that determined patient care setting (freestanding clinic, hospital with or without cardiac surgical support).

### Evidence Base

Our searches did not identify any published studies that directly addressed this question. Since patients at freestanding catheterization centers have typically received only diagnostic procedures, we evaluated only studies of diagnostic procedures for this question. Although there are several relevant studies, none has clearly identified prognostic factors that influenced the physician’s decision to treat patients in a given care setting. We therefore looked for studies that indirectly addressed the question.

In this indirect approach, we examined the patient inclusion/exclusion criteria of published studies. Thus, we re-examined all 23 studies that met our criteria for Key Question 1. Studies that reported no information on inclusion/exclusion criteria were excluded from further consideration. Seventeen of the 23 studies reported sufficient information to be included for this question. These studies are listed in Table 6. The excluded studies appear in Table B-1 (Appendix B) along with the reason for exclusion.

Table 6 Evidence Base for Key Question 4

Study Design | References
Randomized Controlled Trials | Block et al.(21)
Case series | Peterson and Peterson(23); Bersin et al.(24); Elliott et al.(25); Clements and Gatlin(27); Kern et al.(28); Murray and Rothman(29); Oldroyd et al.(30); Pink et al.(31); Murdock et al.(32); Mahrer et al.(33); Fighali et al.(34); Klinke et al.(35); Diethrich et al.(37); Gavin et al.(39); Mahrer and Eshoo(38); Baird(42)

### Quality of Included Studies

None of the included studies directly studied prognostic factors related to patient referral to a particular care setting. Thus, the quality of all of these studies is low.

### Details of Study Enrollees and Study Generalizability

None of the study populations were found to be completely generalizable to the Medicare population. All of the studies that reported age had some overlap with the Medicare population, but the age ranges were generally large, ranging from adolescent or young adult to elderly. Furthermore, females tended to be underrepresented in these studies relative to the Medicare population. Therefore, the generalizability of the studies to the Medicare population was “Fair.”^4^ Details of the patients enrolled in these studies are presented in Table C-2 and Table C-3 of Appendix C.

4 High = Characteristics of all enrolled patients typical of Medicare population; Fair = Characteristics of some enrolled patients typical of Medicare population; Poor = Characteristics of only a few enrolled patients typical of Medicare population or enrolled patients represent a subgroup of Medicare population.

### Findings of Included Studies

The two studies of freestanding catheterization clinics and the fifteen studies of hospital outpatient catheterization laboratories (see Table E-1, Appendix E) generally included patients who were clinically stable, and excluded one or more subgroups of those considered at high risk (Class IV cardiac disease, refractory unstable angina, severe congestive heart failure, and recent MI were the most common reasons for exclusion). The majority of studies excluded at least some proportion of higher risk patients, although there was minor variability in the subgroups of patients excluded.

The ACC/SCAI Clinical Expert Consensus Document on Cardiac Catheterization Laboratory Standards recommends slightly different exclusion criteria for diagnostic catheterization in hospital and freestanding settings. Patients thought to be at an increased risk for complications are recommended to be sent to hospitals with cardiac surgical support. Thus, in hospitals without cardiac surgical support, the document recommends the following exclusion criteria for adult patients:

- age >75 years
- NYHA Class III or IV heart failure
- acute, intermediate or high risk ischemic syndromes
- Recent MI with post-infarction ischemia
- Pulmonary edema thought to be caused by ischemia
- Markedly abnormal noninvasive test indicating a high likelihood of left main or severe multivessel coronary disease
- Known left main coronary artery disease
- Severe valvular dysfunction, especially in the setting of depressed left ventricular performance
- Patients at increased risk for vascular complications
- Complex adult congenital heart disease

For freestanding laboratories, the document recommends using all of the above exclusion criteria with the additional exclusion of patients at high risk due to the presence of comorbid conditions, including the need for anticoagulation therapy, poorly controlled hypertension or diabetes, contrast allergy, or renal insufficiency.(1) These recommendations were published in 2001, which is more recent than most of the published studies evaluating diagnostic catheterization.

Although these recommendations were based on expert consensus, evidence from a published multivariable model for predicting complication risk during diagnostic cardiac catheterization is consistent with some of the above-listed criteria. Based on an analysis of the 1990 SCAI database of diagnostic cardiac catheterization procedures, this study found that unstable angina, congestive heart failure, cardiomyopathy, aortic valve disease, shock, acute MI <24 hrs, multivessel disease, hypertension, and NYHA Class IV were significant independent predictors of an increased complication risk during these procedures (inpatient and moribund status were also independent predictors, but these cases are unlikely to be seen at freestanding clinics).(54)

### Subsection Summary

We found no studies that directly addressed this question, but the patient inclusion criteria in 17 of 23 studies from Key Question 1 indirectly provide relevant information. The quality of these studies was low, and their generalizability to the Medicare population was fair.

Both freestanding and hospital outpatient studies included clinically stable patients and excluded one or more subgroups of higher risk patients (with recent MI, Class IV cardiac disease, refractory unstable angina, and severe congestive heart failure, among others). Minor variability appeared in the specific subgroups of patients excluded among the different studies.

An ACC/SCAI expert consensus document recommended similar but slightly more stringent exclusion criteria for freestanding settings than for hospitals without cardiac surgical support. A published multivariable model for predicting complication risks during cardiac catheterization procedures is consistent with some of these recommendations.

## Key Question 5 What Are the Current State Regulations, Certificate of Need (CON) Requirements, and Oversight Procedures for Freestanding Cardiac Catheterization Clinics?

This question consists of a review summarizing regulations concerning freestanding cardiac catheterization clinics from all 50 states. Also included is a review of relevant regulations and guidelines from the United Kingdom and Canada.

### Question-Specific Inclusion/Exclusion Criteria

To address this question, we considered any type of information related to state regulations, Certificate of Need requirements (CON), and oversight procedures for freestanding catheterization clinics in the U.S. Regulatory information from the U.K. and Canada was also included.

### Evidence Base

Our searches identified web documents describing state regulations for freestanding cardiac catheterization clinics. Some documents had no specific language regarding cardiac catheterization or freestanding clinics, but were still relevant (e.g., in certain cases they indicated that the procedures or procedural settings were unregulated). The searches also identified documents describing similar regulations in the U.K. and Canada.

### Quality of Included Studies

Because this question involves only reporting existing regulations, assessment of study quality is not relevant.

### State Regulations

#### States that Do Not Prohibit Freestanding Cardiac Catheterization Facilities

The following states currently do not prohibit cardiac catheterization services in freestanding settings: Alabama, Alaska, Arizona, Arkansas, California, Connecticut, Florida, Georgia, Hawaii, Idaho, Illinois, Indiana, Kansas, Kentucky, Louisiana, Maine, Maryland, Minnesota, Missouri, Montana, Nebraska, Nevada, New Mexico, North Dakota, Oklahoma, Oregon, Rhode Island, South Carolina, South Dakota, Tennessee, Texas, Utah, Virginia, Washington, West Virginia, Wisconsin, and Wyoming. The District of Columbia also does not prohibit cardiac catheterization services in a freestanding setting. Table F-1 in Appendix F contains regulatory information relevant to freestanding cardiac catheterization services in each of these states.

Although these states have no regulations prohibiting such facilities, sources in 13 (Alabama, Alaska, Connecticut, Hawaii, Maine, Minnesota, Montana, Nebraska, Nevada, North Dakota, Oregon, Rhode Island, West Virginia, plus D.C.) reported that they were unaware of any freestanding diagnostic catheterization clinics currently operating in those states.

#### States with Regulations Prohibiting Freestanding Cardiac Catheterization Facilities

The following states have regulations that prohibit the performance of cardiac catheterization procedures in a freestanding setting: Colorado, Delaware, Iowa, Massachusetts, Michigan, Mississippi, New Hampshire, New Jersey, New York, North Carolina, Ohio, Pennsylvania, and Vermont. Table F-2 in Appendix contains specific information concerning the regulations prohibiting freestanding cardiac catheterization services in each of these states.

Two states with regulations prohibiting freestanding catheterization facilities have made exceptions to allow diagnostic catheterization procedures in at least one freestanding facility. The Pennsylvania Department of Health has made an exception for one freestanding center in Philadelphia as part of a demonstration project.(11) If the performance is satisfactory over the trial period, permits may be issued for other such facilities. New Jersey does not currently allow freestanding catheterization facilities, but one freestanding facility is currently operating because it was established as a “private practice of medicine” prior to a statutory change in 1991. Since it was established as a private practice, it is not subject to licensure or any other regulation by New Jersey’s Department of Health and Senior Services.(55)

Although Colorado generally prohibits cardiac catheterization procedures in freestanding settings, this is not true if an ambulatory surgical center is hospital-owned. If so, it does not require a separate license from the state, even if it is not on the same campus as the owner hospital. In this case, the center is free to perform cardiac catheterization procedures. According to a source at the ACC-NCDR database, at least one freestanding facility is currently performing these procedures in Colorado.(56)

#### Certificate of Need (CON) Laws

If hospitals or medical practices wish to expand or initiate certain healthcare services within a given community, CON laws require them to prove that a need for such services exist within that community. Currently, 36 states plus Washington, D.C. have CON laws, with variations in each state regarding what services are regulated and the minimum economic thresholds that require state review of projects.(57)

Of the 36 states (plus the District of Columbia) with CON laws, 25 (plus D.C.) have CON laws specifically pertaining to cardiac catheterization services. Of these 25 states, 16 (Alabama, Alaska, Connecticut, Georgia, Hawaii, Illinois, Kentucky, Maine, Maryland, Missouri, Rhode Island, South Carolina, Tennessee, Virginia, Washington, and West Virginia) currently do not prohibit freestanding cardiac catheterization facilities and regulate them through CON (see Table F-1 for regulatory information). The remaining nine (Delaware, Iowa, Michigan, Mississippi, New Hampshire, New Jersey, New York, North Carolina, and Vermont) have regulations prohibiting cardiac catheterization in freestanding settings (see Table F-2 for regulatory information).

Further details regarding state CON laws can be found in the 2005 edition of the National Directory of Health Planning, Policy, and Regulatory Agencies.(58)

### Joint Commission on Accreditation of Healthcare Organizations (JCAHO) Standards

JCAHO is an independent, not-for-profit organization that conducts surveys of healthcare organizations to determine whether they meet certain functional standards related to safety and quality of care. Healthcare organizations that meet the standards after an on-site survey by a team of Joint Commission healthcare professionals receive accreditation. To maintain accreditation, an organization must be surveyed at least once every three years (except for laboratories, which must be surveyed every two years).(59) JCAHO standards are not enforceable by law; they are intended to provide a benchmark of performance that healthcare organizations should attain.

JCAHO functional standards are grouped into nine “chapters”: 1) Ethics, rights, and responsibilities, 2) Provision of care, treatment, and services, 3) Medication management, 4) Surveillance, prevention, and control of infection, 5) Improving organization performance, 6) Leadership, 7) Management of the environment of care, 8) Management of human resources, and 9) Management of information. The standards that apply to cardiac catheterization laboratories appear in Table F-3, Appendix F. Further details on standards, including elements of performance used to assess an organization’s compliance with standards, can be found in the 2005–2006 Comprehensive Accreditation Manual for Ambulatory Care.(60)

### Regulations in Canada and the U.K

Currently, Health Canada guidelines do not directly specify that cardiac catheterization laboratories must be located in hospitals.(61) Since Canada does not have a national policy on cardiac catheterization services, regulation occurs at the level of the provincial governments. Of the 13 Canadian provinces and territories, only four responded to our requests for information. These provinces (Alberta, Manitoba, Nova Scotia, and Saskatchewan) all reported that cardiac catheterization services are only performed in hospital settings (although a source in Manitoba stated that no specific regulation prohibited these services in freestanding settings).(62–65) A source in Saskatchewan stated that all insured health services are provided only in hospitals, and cardiac catheterization is an insured service.(65)

The United Kingdom does not allow any cardiac catheterization procedures to be performed outside of a hospital setting.(66)

### Subsection Summary

Currently, 37 states (plus D.C.) do not prohibit diagnostic cardiac catheterization procedures in a freestanding setting. In these states, regulation usually occurs through CON programs (16 states plus D.C.). However, 16 states without CON programs have no regulations or licensure requirements for such clinics. Sources in 13 states (plus D.C.) that do not prohibit freestanding catheterization services reported that there were no such facilities (or at least they were not aware of any) currently operating in these states.

Thirteen states have regulations prohibiting cardiac catheterization in freestanding clinics. In three of these states, pilot programs or regulatory loopholes have allowed at least one freestanding facility to perform cardiac catheterization procedures.

Any facility performing cardiac catheterization procedures can voluntarily seek JCAHO accreditation. The facility must meet several functional standards to gain accreditation.

The United Kingdom does not allow any cardiac catheterization procedures to be performed outside of a hospital setting. Canada has no specific regulatory prohibitions on the national level, and four provinces did not report specific prohibitions, but all four reported that no freestanding facilities were performing cardiac catheterization procedures. We cannot confirm whether any freestanding facilities perform these procedures in the remaining nine Canadian provinces and territories.

## Conclusions

The available evidence (consisting of 24 case series) did not reveal substantial differences in complication rates of diagnostic catheterization procedures among freestanding clinics (five studies) and hospital outpatient settings (19 studies). However, this indirect and informal comparison of low quality studies could not be risk-adjusted to compensate for differences in patient characteristics among the studies. Also, none of the freestanding clinic studies reported the length of followup; if it was shorter than the average followup in the hospital outpatient studies, this would create bias in the comparison. Furthermore, we cannot determine whether the relatively low complication rates reported in freestanding studies are generalizable to all freestanding centers, as this evidence base was susceptible to potential publication bias. Since all freestanding clinic studies and most hospital outpatient studies were published in the 1980s, the degree of relevance of the findings to current clinical practice is also unknown. These weaknesses in the evidence base mean that we cannot completely rule out the possibility of differences in complication rates between these settings.

No evidence-based conclusion was possible regarding interventional coronary procedures in freestanding centers. An ACC/SCAI expert consensus document recommended that such procedures not be performed in freestanding settings, and we found no information to suggest that PCI procedures are currently being performed in this setting. Thus, patients who may be potential candidates for combined diagnostic and PCI procedures during a single visit do not have that option in a freestanding clinic. The PCI procedure must be scheduled for another time at a hospital that performs interventional procedures.

This report also evaluated outcomes of PCI procedures at hospitals with and without surgical support. However, hospitals without cardiac surgical support are an imperfect surrogate for freestanding clinics, because even hospitals without cardiac surgical support have support services and resources beyond what is typically found in freestanding settings. Thus, one cannot be certain to what extent, if any, the findings for interventional procedures in a hospital setting can be extrapolated to a freestanding setting.

Three non-randomized controlled studies of non-primary PCI procedures in hospitals with and without cardiac surgical backup reported conflicting results. Two studies showed no difference in complication rates while the remaining study (the only study that exclusively evaluated Medicare patients) showed significantly higher mortality at hospitals without cardiac surgical support. Because these studies were vulnerable to selection bias and differed from each other in several characteristics, the conflicting results cannot be explained with certainty.

Six non-randomized controlled studies of primary PCI showed consistent findings of no statistically significant difference in rates of mortality or serious morbidity between hospitals with and without cardiac surgical backup. Three of these studies adjusted for differences in patient risk. However, all of these studies were vulnerable to selection bias to a greater or lesser degree, and some may have lacked adequate statistical power to detect a meaningful difference in rates. These flaws in the evidence base mean that failure to demonstrate a difference does not eliminate the possibility that a difference may exist.

Characteristics of patients undergoing cardiac catheterization procedures in freestanding settings and hospital outpatient settings could only be addressed indirectly by examining inclusion/exclusion criteria of freestanding and hospital outpatient case series. Two freestanding clinic studies and 15 hospital outpatient studies included clinically stable patients and excluded one or more categories of higher risk patients (with recent MI, Class IV cardiac disease, refractory unstable angina, and severe congestive heart failure, among others). Minor variability appeared in the specific subgroups of patients excluded among the different studies.

An ACC/SCAI expert consensus document recommended similar but slightly more stringent exclusion criteria for freestanding settings than for hospitals without cardiac surgical support. A published multivariable model for predicting complication risks during cardiac catheterization procedures is consistent with some of these recommendations.