# BACKGROUND

## Cardiac Catheterization

Cardiac catheterization is the current standard of care for many patients for the diagnosis and treatment of coronary artery disease (CAD). It is a minimally invasive procedure in which a catheter is guided through blood vessels in the arm or leg into the left or right side of the heart. Once in place, the catheter is used to perform hemodynamic assessments which include measuring pressures within the heart, heart muscle function (cardiac output) and oxygen saturation.(2) The majority of diagnostic catheterizations are performed in the left heart. Right heart catheterization is a diagnostic procedure usually targeted toward patients with heart failure, valvular disease, or congenital heart disease. Some patients undergo combined left and right heart catheterization.

Catheters are also used to inject x-ray contrast dye, which enables identification of arterial blockages via coronary angiography (also referred to as coronary arteriography). Angiography is considered the standard for defining the site, severity, and morphology of lesions. This technology can also aid the qualitative assessment of coronary blood flow and the identification of collateral vessels. Combined analysis of coronary angiograms and left ventriculograms (angiographic studies of the left ventricle) can identify potentially salvageable myocardial tissue that may benefit from an interventional revascularization procedure.(2)

Two additional catheter-based diagnostic procedures are worth noting. Intravascular ultrasound (IVUS) is a catheter-based vascular imaging procedure that has become a valuable adjunct to angiography in recent years.(3) A related procedure that is not widely used is intracardiac echocardiography (ICE). Whereas IVUS is generally used in smaller blood vessels (such as the coronary arteries), ICE is used for imaging cardiac chambers and major blood vessels (such as the aorta).(4)

Diagnostic catheterization is routinely performed on patients in acute care facilities across the U.S. In some states, diagnostic catheterization procedures are also performed in freestanding clinics.

Recent advances in non-invasive imaging technologies, such as multislice CT angiography may decrease demand for minimally invasive diagnostic catheterizations. Conversely, these non-invasive technologies may lead to increases in the number of patients screened, which, in turn, could increase the number of patients receiving interventional catheterization procedures.(5)

Approximately 30% of patients who undergo diagnostic catheterization in an outpatient setting must subsequently undergo interventional catheter-based procedures or surgery (e.g., coronary artery bypass grafting). The most common interventional catheterization procedures are percutaneous coronary interventions (PCI), specifically, percutaneous transluminal coronary angioplasty (PTCA) with or without stents. Drug-eluting stents are currently used in >90% of PCI procedures in the U.S.(6) These procedures are used to open blocked or constricted coronary arteries. Valvuloplasty is a procedure similar to angioplasty but uses a balloon to expand a constricted heart valve rather than a constricted artery.

In recent years, diagnostic catheterization procedures have increasingly been combined with PCI procedures during the same hospital visit if the diagnostic catheterization indicates a need for intervention. Combining the procedures may lower the overall cost associated with these procedures. The alternative is a staged approach where the PCI is scheduled for a later visit. Patients who go to freestanding clinics or diagnostic-only hospitals do not have the option of a combined procedure, because the PCI must be performed at a different institution. However, not all patients are considered good candidates for a combined procedure. Although combined procedures may be less costly, they may place certain patients at higher risk of complications.(7, 8)

Although many states restrict PCI to hospitals with cardiac surgery backup, some states have made an exception for emergency primary angioplasty as an alternative to thrombolytic drug therapy for acute ST-elevation myocardial infarction patients. Whether PCI procedures can successfully be performed in facilities lacking on-site surgical backup may affect the future treatment of CAD patients.(9)

## Freestanding Cardiac Catheterization Clinics

According to an expert consensus document issued jointly by the American College of Cardiology (ACC) and the Society for Cardiac Angiography and Interventions (SCAI) in 2001, a freestanding catheterization laboratory is not physically attached to a hospital, and quick transportation of a patient to a hospital by gurney is not possible.(1) Although some hospitals build catheterization laboratories adjacent to their primary facility, many such laboratories are privately owned.

The ACC/SCAI document further mentions recommended requirements for freestanding laboratories. The committee states that “it is the responsibility of each freestanding laboratory to have a formal relationship with at least 1 tertiary referral hospital so that a written established plan for the emergency transfer of patients is in place. Furthermore, freestanding facilities must have the necessary equipment for intubation and ventilatory support. Physicians using these facilities must be capable of performing endotracheal intubation and inserting an intra-aortic balloon pump. Appropriate quality assurance (QA) and ongoing quality improvement (QI) programs must be established in writing and documented. Oversight has traditionally been provided by a tertiary referral hospital, but alternatives that comply with the maintenance of the highest concern for patient care may be used if acceptable by local standards and if a well-defined QA program is operative.”(1)

The most recent SCAI survey of cardiac catheterization laboratories (published in 1999) identified 58 non-hospital-based laboratories in the U.S., up from 16 in the 1993 survey.(10) This number might be higher if freestanding catheterization laboratories were allowed in all 50 states (see Findings of Included Studies, Key Question 5, for a list of states that allow freestanding catheterization clinics).

The demand for diagnostic catheterization in freestanding settings has arisen in part from long waiting times in certain hospitals that perform diagnostic and interventional catheterization procedures. Because urgent or emergent patients who require PCI must take precedence, low-risk patients scheduled for diagnostic procedures sometimes have to wait all day or even be rescheduled for another day. By providing a setting exclusively for low-risk diagnostic procedures, freestanding clinics can eliminate the long waiting periods that sometimes occur in a hospital setting.(11) Cost-savings and stricter credentialing of physicians have also been reported as advantages of freestanding facilities.(12)

Reported concerns about freestanding catheterization clinics include the ability to maintain an adequate case load to ensure experienced operators, the potential for lapses in quality control mechanisms, and the time required to transfer patients to hospitals in the event of emergency.(12, 13) Some experts have also expressed concerns that the development of some freestanding labs has been driven not by actual patient need but “almost exclusively by a desire to capture market share.”(14) Because such facilities are often physician-owned, the potential exists for financial incentives to inappropriately influence the development of freestanding catheterization clinics. Such incentives might conflict with the publication of procedural outcomes, contributing to potential publication bias (through suppression of negative results) in the body of literature concerning this topic.(6)

Mobile cardiac catheterization laboratories (that can move between facilities) can be based at hospitals with or without surgical backup or in freestanding settings. Mobile labs based in the latter environment may be classified as freestanding labs.(1)

### Procedures Performed in Freestanding Catheterization Clinics

The primary procedure performed at these freestanding clinics is coronary arteriography, which requires arterial access and is performed by advancing catheters to the coronary artery. Cardiac catheterization for evaluation of hemodynamics is also performed in these settings. Although the majority of diagnostic catheterizations are performed in the left heart (including left ventriculography), some patients have undergone right heart, or combined left and right heart catheterization, in a freestanding setting. These are considered to be lower-risk procedures than coronary arteriography. Whether other diagnostic catheterization procedures (such as IVUS, ICE, or EPS) have been performed in a freestanding center is not clear, as no published literature has yet addressed this issue. However, IVUS and ICE are generally used in specialized circumstances in facilities that perform interventional procedures, so they are less likely to be used in a freestanding clinic. Because EPS only requires monitoring and the risk of surgery is negligible, it is perhaps more likely to be used in freestanding settings now or in the future.(6)

An interventional procedure that may possibly be used in some freestanding labs is peripheral artery angioplasty/stenting, which is considered to have a lower complication risk than coronary angioplasty/stenting. However, this has not been reported in the published literature. We have found no information suggesting that coronary interventional procedures are currently performed in freestanding clinics.

### Current CMS Policy Regarding Cardiac Catheterization in Freestanding Clinics

Current CMS policy appears in the NCD for Cardiac Catheterization Performed in Other than a Hospital Setting (20.25). The benefit category is listed as Diagnostic Tests. The indications and limitations of coverage section states that “cardiac catheterization performed in a hospital setting for either inpatients or outpatients is a covered service. The procedure may also be covered when performed in a freestanding clinic when the carrier, in consultation with the appropriate Quality Improvement Organization (QIO), determines that the procedure can be performed safely in all respects in the particular facility. Prior to approving Medicare payment for cardiac catheterizations performed in freestanding clinics, carriers must request QIO review of the clinic.”(15)

However, according to the NCA Tracking Sheet for Cardiac Catheterization Performed in Other than a Hospital Setting, “(QIOs) ceased doing reviews of core freestanding, cardiac catheterization facilities in the early 1990s. Since the implementation of Coverage Issues Manual (CIM) 35–45, we are unaware of any emerging evidence that there is a greater risk of adverse events at these freestanding clinics. Therefore, CMS is opening this policy to review the evidence and correct the discrepancy.”(16)

### Training and Credentialing of Personnel in Freestanding Cardiac Catheterization Clinics

We found no documents specifically pertaining to training/credentialing of personnel in freestanding catheterization clinics. Personnel in these clinics most likely follow the same training/credentialing protocols as personnel in hospital environments.

According to an ACC Task Force document on training in cardiac catheterization, “Level 2” training is required for independent diagnostic catheterization and angiography. This requires all the components of “Level 1” training, which covers “formal training in radiation physics, radiation safety, fluoroscopy and radiologic anatomy, as well as clinical cardiovascular physiology.” Level 1 also requires some experience with pulmonary artery catheterization, left and right heart catheterization, temporary right ventricular pacemaker insertion, and pericardiocentesis. Level 2 requires further training in percutaneous arterial entry and arterial incision and repair, additional education in radiation physics and safety, and a working knowledge of catheterization laboratory equipment. Knowledge of the principles of cardiac output determination, shunt detection, and pressure waveform recording and analysis is mandatory. Additional training in endomyocardial biopsy techniques and intraaortic balloon counterpulsation insertion and management is required. Finally, specialized training (including one month in a pediatric catheterization laboratory) is required for catheterization of patients with complex congenital heart disease.(17)

## Clinical Practice Guidelines

An ACC/SCAI expert consensus document issued jointly in 2001 is the only document published in the last five years to make recommendations about the procedures that can safely be performed in a cardiac catheterization laboratory in all potential care settings (freestanding, hospital without cardiac surgical support, or hospital with cardiac surgical support). The recommendations are based predominantly on expert consensus (the committee believed that the evidence base was not sufficiently well-developed to be evaluated by the formal ACC/American Heart Association (AHA) Practice Guidelines process).

This consensus document states that diagnostic catheterization procedures can be performed in any of the three care settings listed above, although the recommended patient selection criteria vary among different settings. Hospitals with cardiac surgical support have no recommended patient exclusion criteria, while freestanding facilities have the highest number of recommended patient exclusion criteria (see Findings of Included Studies, Key Question 4, for further information on patient selection criteria).

The consensus document also makes recommendations about interventional procedures. It states that “interventional procedures of any kind should not be performed in a freestanding facility.” Also, elective interventional procedures are generally not recommended in hospitals without cardiac surgical support. Primary PCI (for MI) is acceptable in hospitals without cardiac surgical support if there is a proven plan for rapid access (within one hour) to a nearby facility with cardiac surgery support and appropriate hemodynamic support capability for transfer. The document further recommends that primary PCI be performed by experienced practitioners (those performing ≥75 PCIs/year) at facilities performing a minimum of 36 primary PCIs/year. The committee did not reach consensus regarding a minimum necessary caseload for diagnostic catheterization.(1)

A 2001 clinical guideline issued by the ACC/AHA makes recommendations regarding the appropriate care setting for PCI. The document “recommends that primary PCI for acute MI performed at hospitals without established elective PCI programs should be restricted to those institutions with a proven plan for rapid and effective PCI as well as rapid access to cardiac surgery in a nearby facility.” The committee further recommends “that elective PCI should not be performed in facilities without on-site cardiac surgery.”(18)

## Ongoing Trials

Our searches (Appendix A) did not identify any ongoing trials involving freestanding cardiac catheterization clinics. We identified one ongoing nationwide multicenter study (40 hospitals) comparing the use of elective PTCA among 13,000 patients in hospitals with and without cardiac surgical backup. The lead investigator is Dr. Thomas Aversano at Johns Hopkins University School of Medicine.(19)