# Regulations and Standards (Key Question 5)

Table F-1 Regulations in States that Do Not Prohibit Cardiac Catheterization in Freestanding Settings

State | Regulation | Regulating body
Alabama | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(78,79) | State Health Planning and Development Agency
Alaska | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application, unless built by a physicians group (and not defined as a health care facility) or if the cost was below the state’s CON threshold of $1 million.. Interventional catheterization procedures are limited to hospitals with cardiac surgical support.(80) | Department of Health and Social Services
Arizona | Freestanding cardiac catheterization facilities are allowed and licensed under the category “outpatient treatment centers”. This category prohibits any procedures that would require an overnight stay.(81,82) | Arizona Department of Health Services
Arkansas | As long as the procedures performed do not include (a) surgical procedures; nor (b) the use of general or intravenous anesthetics; and, (c) in the opinion(s) of the attending physicians, hospitalization is not necessary, a clinic or office does not fall within the Arkansas definition of an Ambulatory or Outpatient Surgical Center (“ASC”), nor of a Hospital.(83) Arkansas currently has no regulations that require licensure under the above-described conditions, and a freestanding cardiac catheterization facility could meet all of these conditions. | None
California | According to the California Health and Safety Code, Section 100921-100922, “a freestanding cardiac catheterization laboratory that as of December 31, 1993, was in active status in the Health Care Pilot Project…..may be licensed by the State Department of Health Services as a freestanding cardiac catheterization laboratory.” These laboratories are “subject to the Department’s regulations that govern cardiac catheterization laboratories operating in hospitals without facilities for cardiac surgery,” as well as other general regulations. The laboratories must also have a system for the ongoing evaluation of their operations and the services they provide, including a written plan for evaluating the efficiency and effectiveness of the health care services provided.(84) | California Department of Health Services
Connecticut | According to a source at the Office of Health Care Access, No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(85) | Office of Health Care Access
District of Columbia | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(86) | State Health Planning and Development Agency
Florida | There are no state licensure requirements for freestanding cardiac catheterization facilities.(87) Inpatient cardiac catheterization facilities are regulated through the CON program.(88) | None (for freestanding facilities)
Georgia | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. According to Rules and Regulations of the State of Georgia 272-2-.09 (Standards and Criteria, amended), “for CON purposes, Adult Cardiac Catheterization Services is classified as a new institutional health service which must be delivered in a permanently fixed location in either an acute care hospital or in a diagnostic, treatment, or rehabilitation center (DTRC). A CON will be required prior to the establishment of a new or expanded adult cardiac catheterization service.” Interventional catheterization procedures must be performed in acute care hospitals with open heart surgery services or in a hospital that has a Department-approved written agreement for open heart surgery backup with an adjacent acute care hospital.(89) | Division of Health Planning, Department of Community Health
Hawaii | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(90) | State Health Planning and Development Agency
Idaho | No law or regulation prohibits cardiac catheterization in a freestanding setting.(91) However, any procedure requiring an overnight stay must be performed in a hospital setting. | None
Illinois | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. The Illinois Administrative Code 205.135 (Diagnostic Catheterization Procedures) contains further details of the requirements that must be met for diagnostic catheterization procedures to be performed in this setting.(92) | Department of Public Health
Indiana | Freestanding cardiac catheterization facilities are licensed as “ambulatory surgical centers” under the Indiana Administrative Code 410 IAC 15-2.(93) | Indiana State Department of Health
Kansas | No law or regulation prohibits cardiac catheterization in a freestanding setting.(94,95) | None
Kentucky | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. Currently, only one is operating in the state.(96) | Office of Certificate of Need
Louisiana | No law or regulation prohibits cardiac catheterization in a freestanding setting, and there are no licensing requirements for such facilities.(97) | None
Maine | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(98) | Bureau of Elder and Adult Services, Department of Health and Human Services
Maryland | Freestanding cardiac catheterization facilities are allowed and regulated under the licensure category “freestanding ambulatory care facility/major medical equipment facility.” Licensure requires a CON or an exemption from CON. (Code of Maryland Regulations 10.05.03, Freestanding Major Medical Equipment Facilities).(99) | Department of Health and Mental Hygiene
Minnesota | No law or regulation prohibits cardiac catheterization in a freestanding setting. The Department is not aware of any freestanding clinics currently offering these services in the state. | None
Missouri | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program.(100) | Department of Health and Senior Services
Montana | No law or regulation prohibits cardiac catheterization in a freestanding setting, as long as patients do not require an overnight stay (this would require that the procedure take place in a hospital). (Montana Code Annotated 50-5-101). A source at the Licensure Bureau was unaware of any freestanding cardiac catheterization clinics operating at present in Montana.(101) | None
Nebraska | No law or regulation prohibits cardiac catheterization in a freestanding setting, except if a patient requires a stay >24 hours, in which case the site would require licensing as a hospital. Sources at the Department of Health and Human Services were unaware of any freestanding cardiac catheterization facilities currently operating within the state.(102,103) | None
Nevada | No law or regulation prohibits cardiac catheterization in a freestanding setting, except if a patient requires a stay >24 hours, in which case the site would require licensing as a hospital. A source at the State Health Division was unaware of any freestanding cardiac catheterization facilities currently operating within the state.(104) | None
New Mexico | Freestanding cardiac catheterization facilities are allowed under the category “ambulatory surgical center,” which can only provide services that do not require an overnight stay (New Mexico Administrative Code, Title 7, Chapter 11, part 2, Requirements for facilities providing outpatient medical services and infirmaries). These centers are licensed by the Department of Health.(105) | New Mexico Department of Health, Division of Health Improvement, Health Facility License and Certification
North Dakota | No law or regulation prohibits cardiac catheterization in a freestanding setting. A source at the Office of Community Assistance was unaware of any freestanding catheterization clinics currently operating in the state.(106) | None
Oklahoma | No law or regulation prohibits cardiac catheterization in a freestanding setting.(107) | None
Oregon | No requirement that cardiac catheterization facilities be licensed. Freestanding facilities are unregulated. A source at the Office of Public Health Systems was unaware of any freestanding facilities currently performing cardiac catheterization procedures in the state.(108) | None
Rhode Island | No law or regulation prohibits cardiac catheterization in a freestanding setting. Currently, no such services are offered in a freestanding setting; initiation of such a clinic would require a CON application.(109) | Rhode Island Department of Health
South Carolina | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. Currently, only one is operating in the state.(110) | DHEC, Division of Planning and CON
South Dakota | No requirement that cardiac catheterization facilities be licensed. Freestanding facilities are unregulated. | None
Tennessee | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. Currently, 11 have been approved in the state.(111) | Tennessee Health Services and Development Agency
Texas | No law or regulation prohibits cardiac catheterization in a freestanding setting. According to a source at the Texas Department of State Health Services, the procedure can be performed in a licensed ambulatory surgery center.(112) | None
Utah | No law or regulation prohibits cardiac catheterization in a freestanding setting, except if a patient requires an overnight stay, in which case the procedure can only be performed in a hospital.(113) | Utah Department of Health
Virginia | Freestanding cardiac catheterization facilities are allowed and regulated through the CON program. However, the Virginia Administrative Code 5-260-40 (Criteria and Standards for Cardiac Catheterization Services) specifies that “proposals for the use of freestanding or mobile cardiac catheterization services should only be approved if such services will be provided at a site located on the campus of a general/community hospital.”(114) | Virginia Department of Health
Washington | No law or regulation concerns the environment of care in which diagnostic catheterizations are performed. However, interventional catheterizations can only be performed in a hospital setting with an approved CON for heart surgery.(115) | Department of Health
West Virginia | No law or regulation prohibits cardiac catheterization in a freestanding setting. According to a source at the Health Care Authority, no freestanding cardiac catheterization clinics are currently in operation in the state. Initiation of such a clinic would require a CON application.(116) | West Virginia Health Care Authority
Wisconsin | No law or regulation prohibits cardiac catheterization in a freestanding setting.(117) | None
Wyoming | According to a source at the Wyoming Department of Health, the Department “does not require a license for freestanding clinics or any specific procedures in those clinics.”(118) | None

CON – Certificate of Need

Table F-2 Regulations in States that Prohibit Cardiac Catheterization in Freestanding Settings

State | Regulation | Regulating body
Colorado | According to State Board of Health Regulation 6 CCR 1011-1, Chapter XX (Ambulatory Surgical Center), “surgical procedures shall be limited to the following: 1. those that do not exceed 23 hours combined operating and recovery and/or convalescent time, and; 2. those that do not generally result in extensive blood loss, require major or prolonged invasion of body cavities, directly involve major blood vessels, or constitute an emergency or life threatening procedure.”(119) According to a source at the agency, cardiac catheterization is prohibited in ambulatory surgical centers because it directly involves major blood vessels. However, there is a loophole; if an ambulatory surgical center is hospital-owned, it does not require a separate license from the state, and is free of the above restrictions.(120) According to a source at the ACC-NCDR database, at least 1 freestanding facility is performing cardiac catheterization procedures in Colorado.(56) | Department of Public Health and Environment
Delaware | According to a source at the Department of Health and Social Services, “Delaware does not permit such procedures in a freestanding setting. The length of the procedure (plus recovery) is too long to meet the timeframe definition of procedures that may be performed in a freestanding surgical center.” (Procedures cannot exceed 90 minutes and the recovery time cannot exceed 4 hours). “Additionally, a freestanding setting does not provide the emergency/support services that may be necessary when a procedure such as this is performed.” (This position is not codified in writing, but is based on the 1991 American College of Cardiology/ American Heart Association Guidelines for Cardiac Catheterization. This document stated that further development of cardiac catheterization services operating without on-site cardiac surgery facilities “cannot be endorsed at this time” due to a lack of appropriately controlled safety and need data.)(121) | Department of Health and Social Services
Iowa | According to the Iowa Administrative Code, Chapter 203 (Standards for CON Review), “there should be no new cardiac catheterization unit open in any facility not performing open heart surgery.”(122) | Iowa Department of Public Health
Massachusetts | According to the Code of Massachusetts Regulations, Chapter 130.000 (Hospital Licensure), “Cardiac catheterization procedures shall not be performed in a satellite facility or a freestanding clinic.”(123) | Massachusetts Department of Public Health
Michigan | According to a source at the Department of Community Health, “the Michigan CON standards for Cardiac Catheterization do not allow for any cardiac catheterization services to be offered outside of a hospital setting.”(124) | Michigan Department of Community Health
Mississippi | According to a policy statement in the State Health Plan, all cardiac catheterizations and open-heart surgery services must be located in acute care hospitals. No CON will be approved for these services in freestanding facilities or in freestanding ambulatory surgery facilities.(125) | Mississippi Department of Health
New Hampshire | According to the New Hampshire Code of Administrative Rules, He-Hea 1102.01 (Location of Adult Diagnostic Cardiac Catheterization Services), “Adult diagnostic cardiac catheterization services shall only be provided on the campus of an acute care facility.”(126) | New Hampshire Department of Health and Human Services
New Jersey | The New Jersey Administrative Code 8:33E-1.3b states that “all cardiac catheterization procedures, regardless of the category, shall be performed in a hospital-based facility where inpatient services are available on site.”(127) However, one freestanding catheterization facility was established as a private practice of medicine prior to a statutory change in 1991. It is not subject to licensure or regulation by the Department of Health and Senior Services.(55) | New Jersey Department of Health and Senior Services
New York | According to a source at the Department of Health, “New York State does not allow for cardiac cath labs in freestanding clinics. All cardiac cath labs must be within the walls of a hospital.”(128,129) | New York State Department of Health
North Carolina | According to the North Carolina Administrative Code, Section 1600 (Criteria and standards for cardiac catheterization equipment and cardiac angioplasty equipment), applicants for such equipment must provide “documentation that the cardiac catheterization equipment and cardiac angioplasty equipment and the procedures for operation of the equipment are designed and developed based on the American College of Cardiology/ American Heart Association Guidelines for Cardiac Catheterization (1991).” This document stated that further development of cardiac catheterization services operating without on-site cardiac surgery facilities “cannot be endorsed at this time” due to a lack of appropriately controlled safety and need data.(130) | Department of Health and Human Services
Ohio | According to the Ohio Administrative Code, 3701-84-30 (Adult cardiac catheterization service standards), “a cardiac catheterization service shall only be provided in a fully permanent setting within the permanent frame of the building of a registered hospital that is classified as a general hospital or a special hospital-cardia that primarily furnishes limited services to patients with cardiac conditions.”(131) | Ohio Department of Health
Pennsylvania | According to the Pennsylvania Administrative Code, 138.14 (Programs and services), “to perform cardiac catheterization a hospital shall be an acute care facility.”(132) However, the Pennsylvania Department of Health has made an exception for one freestanding center in Philadelphia as part of a demonstration project.(11) | Pennsylvania Department of Health
Vermont | According to the Vermont CON guidelines, Appendix A (Cardiac Catheterization Work Group Recommendations), cardiac catheterization facilities must “be hospital-based, meaning that they are physically located within a hospital or that they be one of (three) types of mobile labs.” These mobile labs cannot operate in a freestanding setting.(133) | Vermont Department of Banking, Insurance, Securities, and Health Care Administration

CON – Certificate of Need

Table F-3 JCAHO Standards Applicable to Cardiac Catheterization Facilities

Standard functional chapter | Standard
Ethics, Rights, and Responsibilities (RI) | Organization Ethics RI.1.10 – the organization follows ethical behavior in its care, treatment, and services and business practices. RI.1.10 – the organization addresses conflicts of interest. RI.1.30 – the integrity of decisions is based on identified care, treatment, and service needs of the patients. RI.1.40 – when care, treatment, and services are subject to internal or external review that results in the denial of care, treatment, services, or payment, the organization makes decisions regarding the provision of ongoing care, treatment, and services, or discharge based on the assessed needs of the patients.
Ethics, Rights, and Responsibilities (RI) | Individual Rights RI.2.10 – the organization respects the rights of patients. RI.2.20 – patients receive information about their rights. RI.2.30 – patients are involved in decisions about care, treatment, and services provided. RI.2.40 – informed consent is obtained RI.2.50 – consent is obtained for recording or filming made for purposes other than the identification, diagnosis or treatment of patients. RI.2.60 – patients receive adequate information about the person(s) responsible for the delivery of their care, treatment, and services. RI.2.70 – patients have the right to refuse care, treatment, and services in accordance with law and regulation. RI.2.80 – the organization addresses the wishes of the patient relating to end-of-life decisions. RI.2.90 – patients and, when appropriate, their families are informed about the outcomes of care, treatment, and services that have been provided, including unanticipated outcomes. RI.2.100 – the organization respects the patient’s right to and need for effective communication. RI.2.110 – not applicable RI.2.120 – the organization addresses the resolution of complaints from patients and their families. RI.2.130 – the organization respects the needs of patients for confidentiality, privacy, and security. RI.2.140 – not applicable RI.2.150 – patients have the right to be free from mental, physical, sexual, and verbal abuse, neglect, and exploitation. RI.2.160 – patients have the right to pain management. RI.2.170 – not applicable RI.2.180 – the organization protects research subjects and respects their rights during research, investigation, and clinical trials involving human subjects.
Ethics, Rights, and Responsibilities (RI) | Individual Responsibilities RI.3.10 – patients are given information about their responsibilities while receiving care, treatment, and services.
Provision of Care, Treatment, and Services (PC) | Entry to Care, Treatment, and Services PC.1.10 – the organization accepts for care, treatment, and services only those patients whose identified care, treatment, and service needs it can meet. Assessment PC.2.10 – not applicable PC.2.20 – the organization defines in writing the data and information gathered during assessment and reassessment. PC.2.30 through PC.2.110 – not applicable PC.2.120 – the organization defines in writing the time frame(s) for conduction the initial assessment(s). PC.2.130 – initial assessments are performed as defined by the organization. PC.2.140 – not applicable PC.2.150 – patients are reassessed as needed. Additional Standards for Victims of Abuse PC.3.10 – patients who may be victims of abuse or neglect are assessed PC.3.20 through PC.3.220 – not applicable Diagnostic Services PC.3.230 – diagnostic testing necessary for determining the patient’s health care needs is perfomed. Planning Care, Treatment, and Services PC.5.10 – the organization provides care, treatment, and services for each patients according to the plan of care, treatment, and services. PC.5.20 through 5.40 – not applicable PC.5.50 – care, treatment, and services are provided in an interdisciplinary, collaborative manner. PC.5.60 – the organization coordinates the care, treatment, and services provided to a patient as part of the plan for care, treatment, and services and consistent with the organization’s scope of care, treatment, and services. Education PC.6.10 – the patient receives education and training specific to the patient’s needs and as appropriate to the care, treatment, and services provided. P.C.6.20 – not applicable P.C.6.30 – the patient receives education and training specific to the patient’s abilities as appropriate to the care, treatment, and services provided. Nutritional Care PC.7.10 – the organization has a process for preparing and/or distributing food and nutrition products as appropriate to the care, treatment, and services provided. Pain PC.8.10 – pain is assessed in all patients. Administering Blood and Blood Components PC.9.10 – blood and blood components are administered safely, as appropriate to the setting. Responding to Life-Threatening Emergencies PC.9.20 – the organization responds to life-threatening emergencies according to organization’s policy and procedure. Restraint and Seclusion PC.11.10 through PC.11.60 – not applicable PC.11.70 – patients in restraint are monitored. PC.11.80 and 11.90 – not applicable PC.11.100 – each episode of restraint use is documented in the patient’s medical record, consistent with organization policies and procedures. Operative or Other High-Risk Procedures and/or the Administration of Moderate or Deep Sedation or Anesthesia PC.13.10 – licensed independent practitioners define the scope of assessment for operative or other procedures and/or the administration of moderate or deep sedation or anesthesia are planned. PC.13.30 – patients are monitored during the procedure and/or administration of moderate or deep sedation or anesthesia. PC.13.40 – patients are monitored immediately after the procedure and/or administration of moderate or deep sedation or anesthesia. Discharge or Transfer from the Organization PC.15.10 – a process addresses the needs for continuing care, treatment, and services after discharge or transfer. PC.15.20 – not applicable PC.15.30 – when patients are transferred or discharged, appropriate information related to the care, treatment, and services provided is exchanged with other service providers. Waived Testing PC.16.10 through 16.60 – not applicable
Medication Management (MM) | Patient-Specific Information MM.1.10 – patient-specific information is readily accessible to those involved in the medication management system. Selection and Procurement MM.2.10 – medications available for dispensing or administration are selected, listed, and procured based on criteria. Storage MM.2.20 – medications are properly and safely stored throughout the organization. MM.2.30 – emergency medications and/or supplies, if any, are consistently available, controlled, and secure in the organization’s patient care areas. MM.2.40 – a process is established to safely manage medications brought into the organization by patients or their families. Ordering and Transcribing MM.3.10 – not applicable MM.3.20 – medication orders are written clearly and transcribed accurately. Preparing and Dispensing MM.4.10 – all prescriptions or medication orders are reviewed for appropriateness. MM.4.20 – medications are prepared safely. MM.4.30 – medications are appropriately labeled. MM.4.40 – medications are dispensed safely. MM.4.50 – the organization has a system for safely providing medications to meet patient needs when the pharmacy is closed. MM.4.60 – if the organization does not operate a pharmacy but routinely administers medications, the organization has a process for obtaining medications from a pharmacy. MM.4.70 – medications dispensed by the organization are retrieved when recalled or discontinued by the manufacturer or the Food and Drug Administration for safety reasons. MM.4.80 – medications returned to the pharmacy are appropriately managed. Administering MM.5.10 – medications are safely and accurately administered. Monitoring MM.6.10 – the effects of medication(s) on patients are monitored. MM.6.20 – the organization responds appropriately to actual or potential adverse drug events and medication errors. High-Risk Medications MM.7.10 – the organization develops processes for managing high-risk or high-alert medications. MM.7.20 and 7.30 – not applicable MM.7.40 – investigational medications are safely controlled and administered. Evaluation MM.8.10 – the organization evaluates its medication management system.
Surveillance, Prevention, and Control of Infection (IC) | The IC Program and Its Components IC.1.10 – the risk of development of a health care-associated infection is minimized through an organizationwide infection control program. IC.2.10 – the infection control program identifies risks for the acquisition and transmission of infectious agents on an ongoing basis. IC.3.10 – based on risks, the organization establishes priorities and sets goals for preventing the development of health care-associated infections within the organization. IC.4.10 – once the organization has prioritized its goals, strategies must be implemented to achieve those goals. IC.5.10 – the infection control program evaluates the effectiveness of the infection control interventions and, as necessary, redesigns the infection control interventions. IC.6.10 – as part of emergency management activities, the organization prepares to respond to an influx, or the risk of an influx, of infectious patients.
Surveillance, Prevention, and Control of Infection (IC) | Structure and Resources for the IC Program IC.7.10 – the infection control program is managed effectively. IC.8.10 – representatives from relevant components/functions within the organization collaborate to implement the infection control program. IC.9.10 – organization leaders allocate adequate resources for the infection control program.
Improving Organizational Performance (PI) | PI.1.10 – the organization collects data to monitor its performance. PI.2.10 – data are systematically aggregated and analyzed. PI.2.20 – undesirable patterns or trends in performance are analyzed. PI.2.30 – processes for identifying and managing sentinel events are defined and implemented. PI.3.10 – information from data analysis is used to make changes that improve performance and patient safety and reduce the risk of sentinel events. PI.3.20 – an ongoing, proactive program for identifying and reducing unanticipated adverse events and safety risks to patients is defined and implemented.
Leadership (LD) | LD.1.10 – the organization identifies how it is governed. LD.1.20 – governance responsibilities are defined in writing, as applicable. LD.1.30 – the organization complies with applicable law and regulation. LD.2.10 – an individual(s) or designee(s) is responsible for operating the organization according to the authority conferred by governance. LD.2.20 – each organizational program, service, site, or department has effective leadership. LD 2.30 and 2.40 – not applicable LD.2.50 – the leaders develop and monitor an annual operating budget and, as appropriate, a long-term capital expenditure plan. LD.3.10 – the leaders engage in both short-term and long-term planning. LD.3.15 – not applicable LD.3.20 – patients with comparable needs receive the same standard of care, treatment, and services throughout the organization. LD.3.30 and 3.40 – not applicable LD.3.50 – services provided by consultation, contractual arrangements, or other agreements are provided safely and effectively. LD.3.60 – communication is effective throughout the organization. LD.3.70 – the leaders define the required qualifications and competence of those staff who provide care, treatment, and services, and recommend a sufficient number of qualified and competent staff to provide care, treatment, and services. LD.3.80 – the leaders provide for adequate space, equipment, and other resources. LD.3.90 – the leaders develop and implement policies and procedures for care, treatment, and services. LD.3.100 and 3.11 – not applicable LD.3.120 – the leaders plan for and support the provision and coordination of patient education activities. LD.3.130 through 3.150 – not applicable LD.4.10 – the leaders set expectations, plan, and manage processes to measure, assess, and improve the organization’s governance, management, clinical, and support activities. LD.4.20 – new or modified services or processes are designed well. LD.4.30 – not applicable LD.4.40 – the leaders ensure that an integrated patient safety program is implemented throughout the organization. LD.4.50 – the leaders set performance improvement priorities and identify how the organization adjusts priorities in response to unusual or urgent events. LD.4.60 – the leaders allocate adequate resources for measuring, assessing, and improving the organization’s performance and improving patient safety. LD.4.70 – the leaders measure and assess the effectiveness of the performance improvement and safety improvement activities. LD.5.10 through 5.40 – not applicable LD.5.50 – clinical practice guidelines are used in designing or improving processes that evaluate and treat specific diagnoses, conditions, and/or symptoms. LD.5.60 – the leaders identify criteria for selecting and implementing clinical practice guidelines. LD.5.70 – appropriate leaders, practitioners, and health care professionals in the organization review and approve clinical practice guidelines selected for implementation. LD.5.80 – the leaders evaluate the outcomes related to clinical practice guidelines and refine the guidelines to improve processes.
Management of the Environment of Care (EC) | Planning and Implementation Activities EC.1.10 – the organization manages safety risks. EC.1.20 – the organization maintains a safe environment. EC.1.25 and 1.27 – not applicable EC.1.30 – the organization develops and implements a policy to prohibit smoking except in specified circumstances. EC.2.10 – the organization identifies and manages its security risks. EC.3.10 – the organization manages its hazardous materials and waste risks. EC.4.10 – the organization addresses emergency management. EC.4.20 – the organization conducts drills regularly to test emergency management. EC.5.10 – the organization manages fire safety risks. EC.5.20 – newly constructed and existing environments are designed and maintained to comply with the Life Safety Code®. EC.5.30 – the organization conducts fire drills regularly. EC.5.40 – the organization maintains fire-safety equipment and building features. EC.5.50 – the organization develops and implements activities to protect occupants during periods when a building does not meet the applicable provisions of the Life Safety Code®. EC.6.10 – the organization manages medical equipment risks. EC.6.20 – medical equipment is maintained, tested, and inspected. EC.7.10 – the organization manages its utility risks. EC.7.20 – the organization provides an emergency electrical power source. EC.7.30 – the organization maintains, tests, and inspects its utility systems. EC.7.40 – the organization maintains, test, and inspects its emergency power systems. EC.7.50 – the organization maintains, tests, and inspectis its medical gas and vacuum systems. EC.8.10 – the organization establishes and maintains an appropriate environment. EC.8.20 – not applicable EC.8.30 – the organization manages the design and building of the environment when it is renovated, altered, or newly created. Measuring and Improving Activities EC.9.10 – the organization monitors conditions in the environment. EC.9.20 – the organization analyzes identified environment issues and develops recommendations for resolving them. EC.9.30 – the organization improves the environment.
Management of Human Resources (HR) | Planning HR.1.10 – the organization provides an adequate number and mix of staff and licensed independent practitioners that are consistent with the organization’s staffing plan. HR.1.20 – the organization has a process to ensure that a person’s qualifications are consistent with his or her job responsibilities.
Management of Human Resources (HR) | Orientation, Training, and Education HR.2.10 – orientation provides initial job training and information. HR.2.20 – staff members, licensed independent practitioners, students, and volunteers, as appropriate, can describe or demonstrate their roles and responsibilities, based on specific job duties or responsibilities, relative to safety. HR.2.30 – ongoing education, including in-services, training, and other activities, maintains and improves competence.
Management of Human Resources (HR) | Assessing Competence HR.3.10 – competence to perform job responsibilities is assessed, demonstrated, and maintained. HR.3.20 – the organization periodically conducts performance evaluations.
Management of Human Resources (HR) | Credentialing and Assignment of Clinical Responsibilities of Licensed Independent Practitioners HR.4.10 – there is a process for ensuring the competence of all practitioners permitted by law and the organization to practice independently. HR.4.20 – individuals permitted by law and the organization to practice independently are granted clinical privileges. HR.4.30 – the organization has a process for granting temporary clinical privileges, when appropriate. HR.4.40 – there are mechanisms, including a fair hearing and appeal process, for addressing adverse decisions regarding reappointment, denial, reduction, suspension, or revocation of clinical privileges that may relate to quality of care, treatment, and service issues. HR.4.50 – clinical privileges and appointments/reappointments are reviewed and revised at least every two years.
Management of Information (IM) | Information Management Planning IM.1.10 – the organization plans and designs information management processes to meet internal and external information needs. Confidentiality and Security IM.2.10 – information privacy and confidentiality are maintained. IM.2.20 – information security, including data integrity, is maintained. IM.2.30 – the organization has a process for maintaining continuity of information. Information Management Processes IM.3.10 – the organization has processes in place to effectively manage information, including the capturing, reporting, processing, storing, retrieving, dissemination, and displaying of clinical/service and nonclinical data and information. Information-Based Decision Making IM.4.10 – the information management system provides information for use in decision making. Knowledge-Based Information IM.5.10 – Knowledge-based information resources are readily available, current, and authoritative. Patient-Specific Information IM.6.10 – the organization has a complete and accurate medical record for every individual assessed, cared for, treated, or served. IM.6.20 – records contain patient-specific information, as appropriate to the care, treatment, and services provided. IM.6.30 – the medical record thoroughly documents operative or other high-risk procedures and the use of moderate or deep sedation or anesthesia. IM.6.40 – for patients receiving continuing ambulatory care services, the medical record contains a summary list of all significant diagnoses, procedures, drug allergies, and medications. IM.6.50 – designated qualified personnel accept and transcribe verbal orders from authorized individuals. IM.6.60 – the organization can provide access to all relevant information from a patient’s record when needed for use in patient care, treatment, and services.