# Evidence Tables for Key Question 3

Table D-1 Study Design Characteristics Pertaining to Internal Validity

Reference | Year | Clear definition of interventions? | Prospective? | Sampling method | All baseline patient characteristics comparable? | Blinding? | Overall Attrition: % (n =) | Differential Attrition: % (n = ) | Adjustment for potential confounders? | Power of study^a^ | USPSTF Quality Rating
Full articles
Sanborn et al.(46,47) | 2004 | Yes | No | Cons | No | No | NR | NR | No | NR | Level II-3-Low
Singh et al.(48) | 2004 | Yes | No | Cons | No | No | NR | NR | Partial | NR | Level-II-3-Fair
Wennberg et al.(49) | 2004 | Yes | No | Cons | No | No | NR | NR | Yes | Sufficient for all outcomes | Level II-3-Fair
Wharton et al.(50) | 1999 | Yes | No | Cons | No | No | NR | NR | No | NR | Level II-3-Low
Weaver et al.(51) | 1995 | Yes | No | Cons | No | No | NR | NR | Yes | NR | Level II-3-Fair
Meeting abstracts
Kutcher et al.(45) | 2004 | Yes | No | Cons | No | No | NR | NR | No | Sufficient for all outcomes | Level II-3-Low
Garratt et al.(52) | 2002 | Yes | No | Cons | No | No | NR | NR | Partial | NR | Level II-3-Fair

Cons – consecutive patients

NA – Not applicable

NR – Not reported

Table D-2 Patient Enrollment Criteria for Studies Addressing Key Question 3

Reference | Year | Inclusion Criteria | Exclusion Criteria
Sanborn et al.(46) | 2004 | Patients with ST-segment elevation admitted between April 1998 and October 2001 and eligible (ST-segment elevation and/or left bundle branch block at presentation <12 hours after onset of pain) for reperfusion (thrombolytics/PCI) were evaluated. | Patients transferred from another hospital and patients transferred out at <48 hours were excluded from the analysis of primary PCI results.
Singh et al.(48) | 2004 | Patients with a diagnosis of acute MI in whom PCI was performed at a single institution over a 14-month period. Comparable patients from the same time period at a tertiary center with cardiac surgical backup were included. | Patients with cardiogenic shock or incessant ventricular tachyarrhythmia and those who had received thrombolytic therapy were excluded. Also excluded were patients who were treated at both institutions.
Wennberg et al.(49) | 2004 | All fee-for-service Medicare enrollees who were aged at least 65 years and who underwent PCIs at acute care facilities between January 1, 1999 and December 31, 2001. Only first procedures were included. | Patients with unknown procedure dates were excluded, as were patients who had CABG surgery during hospitalization but prior to PCI. Patients with PCIs occurring after December 1, 2001 were also excluded to allow 30 days of followup, as were patients who had PCIs in hospitals that opened or closed CABG surgery programs during the study period.
Wharton et al.(50) | 1999 | Consecutive patients with AMI who received PCI at two institutions over a 6-year period. The study population included patients with a clinical impression of AMI: over 30 min of ischemic pain not controlled by conventional medications or an ECG demonstrating ≥2 mV of ST segment elevation in 2 or more contiguous leads. There was no time cutoff if the clinical impression suggested myocardial necrosis. Patients with cardiogenic shock surviving the emergency department were included. Also included were all patients with out-of-hospital ventricular fibrillation who had successful cardioversion in the field, regardless of acute mental status on arrival. | Patients who presented more than 12 h after onset of pain were not included if they were symptom-free on emergency department arrival. Also not included were patients with ventricular septal rupture or papillary muscle rupture, who were taken to the catheterization laboratory for stabilization and IABP before emergent transfer. Angioplasty was not performed if there was Thrombolysis in Myocardial Infarction (TIMI) grade 3 flow in the infarct-related artery (IRA) in hemodynamically stable asymptomatic patients, or if there was significant (≥60%) stenosis of an unprotected left main coronary artery upstream from an acute occlusion in the left coronary system that might be disrupted by the angioplasty catheter. Angioplasty was also avoided in extremely long or angulated infarct-related lesions with TIMI grade 3 flow, infarct-related lesions of small or secondary vessels and lesions in other than the IRA (unless they appeared to be flow-limiting in patients with hemodynamic instability or ongoing symptoms).
Weaver et al.(51) | 1995 | All patients with AMI admitted over a 6-year period at 10 hospitals who were treated using primary coronary angioplasty within 6 hours of admission and who did not receive intravenous thrombolytic therapy. | Patients with MI as a consequence of other illnesses or those with MI after admission for unstable angina were not included. Patients who had cardiac arrest prior to hospital admission and patients who were initially treated by thrombolysis and then underwent angioplasty (rescue angioplasty) were also excluded.
Kutcher et al.(45) (abstract) | 2004 | NR | NR
Garratt et al.(52) (abstract) | 2002 | All patients who received elective PCI at two institutions over a 2-year period. Specific criteria for selection of patients for elective PCI were not reported. | NR

NR – Not reported

Table D-3 Characteristics of Patients Receiving Non-Primary Percutaneous Coronary Intervention

Author/ year | Type of hospital | n | Age (mean±SD) | % female | % prior revascularization | % prior PTCA | % prior CABG | % prior MI | % diabetes | % peripheral vascular disease | % hypertension | % multivessel disease | % COPD | % current smokers | % history of CHF | history of angina | % hypercholesterolemia
Wennberg et al. 2004(49) | Without surgical support | 6373 | NR | 45.5 | NR | NR | NR | 6.8 | 25.6 | 9.4 | NR | NR | 14.4 | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 583149 | NR | 43.2 | NR | NR | NR | 10.5 | 24.8 | 9.4 | NR | NR | 13.3 | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract)^a^ | Without surgical support | 2537 | NR | NR | NR | 26 | 13 | 24 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract)^a^ | With surgical support | 275568 (total – non-primary plus primary) | NR | NR | NR | 35 p <0.0001 | 19 p <0.0001 | 29 p <0.0001 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Garratt et al. 2002(52) (abstract) elective PCI | Without surgical support | 206 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Garratt et al. 2002(52) (abstract) elective PCI | With surgical support | 690 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

a For this study, patient characteristic data only reported for the entire patient group (not divided into primary and non-primary PCI).

NR – Not reported

Table D-4 Additional Characteristics of Patients Receiving Non-Primary Percutaneous Coronary Intervention

Author year | Type of hospital | N | Age (mean ± SD) | % femal | %>50% left main stenosis | % three-vessel disease | % two vessel disease | % single-vessel disease | % mild CAD (lessions ≤50% | % normal angiogram | % valvular disease | % cardiomyopathy | % left ventricular hypertrophy | % congenital disease
Wennberg et al. 2004(49) | Without surgical support | 6373 | NR | 45.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 583149 | NR | 43.2 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) ^a^ | Without surgical support | 2537 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) ^a^ | With surgical support | 275568 (total – non-primary plus primary) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Garratt et al. 2002(52) (abstract) elective PCI | Without surgical support | 206 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Garratt et al. 2002(52) (abstract) elective PCI | With surgical support | 690 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

Table D-5 Characteristics of Patients Receiving Primary Percutaneous Coronary Intervention

Author/ year | Type of hospital | n | Age (mean±) | % female | % prior revascularization | % prior PTCA | % prior CABG | % prior MI | % diabetes | % peripheral vascular disease | % hypertension | % multivessel disease | % COPD | % current smokers | % history of CHF | % history of angina | % hypercholesterolemia
Sanborn et al. 2004(46) | Diagnostic cath without surgical support | 817 | 61.1 (12.7) | 30.5 | NR | 9.6 | 3.3 | 15.1 | 16.4 | NR | 46.8 | NR | NR | 41.3 | 4.4 | 7.2 | 33.8
Sanborn et al. 2004(46) | Elective PCI without surgical support | 1057 | 61.4 (13.1) | 26.7 | NR | 13.2 | 5.7 | 17.7 | 17.3 | NR | 46.6 | NR | NR | 41.6 | 3.7 | 4.9 | 35.5
Sanborn et al. 2004(46) | With surgical support | 24890 | 62.0 (13.1) | 28.8 | NR | 14.6 p = 0.0001 | 6.2 p = 0.002 | 16.9 | 18.4 | NR | 47.9 | NR | NR | 37.2 p = 0.001 | 3.3 | 8.5 p = 0.0001 | 36.7
Singh et al. 2004(48) | Without surgical support | 160 | 64 (13) | 24 | 13 | 11 | 4 | NR | 16 | 9 | 56 | 54 | NR | 29 | 4 | NR | 33
Singh et al. 2004(48) | With surgical support | 160 | 64 (13) | 35 p = 0.04 | 21 p = 0.04 | 17 | 7 | NR | 19 | 5 | 63 | 49 | NR | 33 | 5 | NR | 58 p <0.001
Wennberg et al. 2004(49) | Without surgical support | 1795 | Means NR. See other | 42.7 | NR | NR | NR | 4.6 | 18.2 | 5.3 | NR | NR | 13.9 | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 34537 | | 44.2 | NR | NR | NR | 4.5 | 19.7 | 5.7 | NR | NR | 13.7 | NR | NR | NR | NR
Wharton et al. 1999(50) | Without surgical support | 231 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wharton et al. 1999(50) | With surgical support | 245 | 58 (median) | 25 | NR | 13 | 7 | 21 | 14 | 7 | 50 | NR | NR | 42 | 2 | NR | NR
Weaver et al. 1995(51) | Without surgical support | 470 | 59 (50 to 67) | 21 | NR | 7 | 7 | 13 | 11 | NR | NR | NR | NR | NR | 2 | 23 | NR
Weaver et al. 1995(51) | With surgical support | 592 | 61 (53 to 70) | 27 p = 0.01 | NR | 10 | 9 | 16 | 11 | NR | NR | NR | NR | NR | 4 | 25 | NR
Kutcher et al. 2004(45) (abstract) a | Without surgical support | 2537 | NR | NR | NR | 26 | 13 | 24 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) a | With surgical support | 275568 total – non-primary plus primary) | NR | NR | NR | 35 p <0.0001 | 19 p <0.0001 | 29 p <0.0001 | NR | NR | NR | NR | NR | NR | NR | NR | NR

a For this study, patient characteristic data only reported for the entire patient group (not divided into primary and non-primary PCI).

NR – Not reported

Table D-6 Additional Characteristics of Patients Receiving Primary Percutaneous Coronary Intervention

Author/ year | Type of hospital | N | Age (mean ±SD) | % female | % >50% left main stenosis | % three-vessel disease | % two-vessel disease | % single-vessel disease | % mild CAD (lesions ≤50%) | % normal angiogram | % valvular disease | % cardiomyopathy | % left ventricular hypertrophy | % congenital disease
Sanborn et al. 2004(46) | Diagnostic cath without surgical support | 817 | 61.1 (12.7) | 30.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sanborn et al. 2004(46) | Elective PCI without surgical support | 1057 | 61.4 (13.1) | 26.7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sanborn et al. 2004(46) | With surgical support | 24890 | 62.0 (13.1) | 28.8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Singh et al. 2004(48) | Without surgical support | 160 | 64 (13) | 24 | NR | 54 | | NR | NR | NR | NR | NR | NR | NR
Singh et al. 2004(48) | With surgical support | 160 | 64 (13) | 35 p = 0.04 | NR | 49 (multivessel disease) | | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | Without surgical support | 1795 | Means NR. See other | 42.7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 34537 | | 44.2 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wharton et al. 1999(50) | Without surgical support | 231 | NR | NR | NR | NR | NR | NR | | | NR | NR | NR | NR
Wharton et al. 1999(50) | With surgical support | 245 | 58 (median) | 25 | NR | 18 | 35 | 47 (0 to 1 vessel disease) | | | NR | NR | NR | NR
Weaver et al. 1995(51) | Without surgical support | 470 | 59 (50 to 67) | 21 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Weaver et al. 1995(51) | With surgical support | 592 | 61 (53 to 70) | 27 p = 0.01 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract)^a^ | Without surgical support | 2537 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract)^a^ | With surgical support | 275568 (total – non-primary plus primary) | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

Table D-7 Adverse Events Related to Non-Primary Percutaneous Coronary Intervention (Hospitals With and Without Surgical Support)

Author/ year | Type of hospital | n | Length of followup | % death | % CABG | % reinfarction | % stroke/TIA | % pulmonary edema | % coronary dissection | % embolism | % accelerated angina | % ventricular fibrillation | % ventricular tachycardia | % bradycardia/hypotension/ vasovagal reaction | % allergic reaction | % bleeding/hematoma | % arterial thrombosis/loss of radial pulse | % pseudoaneurysm | % other complications
Wennberg et al. 2004(49) | Without surgical support | 6373 | 30 days | 4.6 | 1.2 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 583149 | | 2.8 p = 0.001 | 1.1 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | Without surgical support | 198555 | NR | 0.46 | 0.62 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | With surgical support | 198555 | | 0.46 | 0.62 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Garratt et al. 2002(52) | Without surgical support | 206 | NR | 0.49 | 0.0 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
(abstract) elective PCI | With surgical support | 690 | | 0.72 | 0.43 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

NR – Not reported

Table D-8 Adverse Events Related to Primary Percutaneous Coronary Intervention (Hospitals With and Without Surgical Support)

Author/ year | Type of hospital | n | Length of followup | % death | % CABG | % reinfarction | % stroke/TIA | % pulmonary edema | % coronary dissection | % embolism | % accelerated angina | % ventricular fibrillation | % ventricular tachycardia | % bradycardia/hypotension/ vasovagal reaction | % allergic reaction | % bleeding/hematoma | % arterial thrombosis/ loss of radial pulse | % pseudoaneurysm | % other complications
Sanborn et al. 2004(46) | Diagnostic cath without surgical support | 817 | IH | 3.2 | 0 | 0.6 | 0.6 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sanborn et al. 2004(46) | Elective PCI without surgical support | 1057 | | 4.2 | 0 | 1.5 | 0.4 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sanborn et al. 2004(46) | With surgical support | 24890 | | 4.8 | 4.9 | 1.2 | 0.7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Singh et al. 2004(48) | Without surgical support | 160 | IH | 1.9 | 0.6 | 0.6 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Singh et al. 2004(48) | With surgical support | 160 | | 1.3 | 0.6 | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | Without surgical support | 1795 | 30 days | 11.3 | 4.6 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wennberg et al. 2004(49) | With surgical support | 34537 | | 12.2 | 5.1 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wharton et al. 1999(50) | Without surgical support | 231 | IH | 3.9 | NR | 3.0 | 0.4 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Wharton et al. 1999(50) | With surgical support | 245 | | 4.0 | NR | 3.0 | 1.0 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Weaver et al. 1995(51) | Without surgical support | 470 | IH | 7 | 8.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Weaver et al. 1995(51) | With surgical support | 572 | | 7 | 12 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | [underlined: ST elev MI] | | NR
Kutcher et al. 2004(45) (abstract) | Without surgical support | 491 | | 4.89 | 1.22 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | With surgical support | 38939 | | 4.89 | 1.19 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | [underlined: Non-ST elev MI] | | NR
Kutcher et al. 2004(45) (abstract) | Without surgical support | 378 | | 2.65 | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kutcher et al. 2004(45) (abstract) | With surgical support | 38005 | | 2.23 | 0.83 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

IH – In-hospital. Duration of hospital stay varied among patients; average duration was not reported.

NR – Not reported