# Evidence Tables for Key Question 1

Table C-1 Patient Enrollment Criteria for Studies Addressing Key Question 1

Reference | Year | Inclusion Criteria | Exclusion Criteria
Jackson(12)^a^ | 1989 | NR | NR
Jackson(12)^b^ | 1989 | NR | NR
Diethrich et al.(37) | 1981 | All patients who received cardiac catheterization in the laboratory over a 20-month period. Patients were selected for catheterization based on their stability and the severity of symptoms. | Patients deemed at high risk (functional Class IV cardiac disease while receiving beta-blockers, highly unstable angina, poorly compensated congestive heart failure, or uncontrolled arrhythmia) were referred to a hospital for invasive study.
Baird(42) | 1980 | All patients who received cardiac catheterization in the laboratory over 4.5 years. Included patients were clinically stable, ambulatory adults with arteriosclerotic, valvular, or congenital heart disease. | Patients were excluded from the clinic if they had recent MI, arrhythmias, severe congestive heart failure, or were hospitalized with unstable angina complicated by hemodynamic impairment or other serious complications requiring intensive care.
Perrigo et al.(41) (abstract) | 1981 | NR | NR
Akdemir et al.(22) | 2004 | NR | NR
Peterson and Peterson(23) | 2004 | All patients undergoing diagnostic catheterization in the mobile lab over a 7-year period. Only stable patients were accepted. | Patients with refractory unstable angina or MI in evolution were transferred to a tertiary center.
Bersin et al.(24) | 1994 | All patients undergoing mobile cardiac catheterization at 8 hospitals in 2 mobile labs over a 20-month period. Patients were selected using criteria described in AHA/ACC guideline for outpatient catheterization. | Criteria described in AHA/ACC guideline for outpatient catheterization. Patients with one or more exclusions were recommended for catheterization at a tertiary facility.
Elliott et al.(25) | 1994 | Patients who did not meet mobile catheterization criteria but were clinically stable enough to enable prescheduling with a planned hospital stay of ≤24 hr. | Patients too unstable to have cardiac catheterization delayed to a prescheduled date.
Clark and Dolce(26) | 1993 | NR | NR
Clements Jr. and Gatlin(27) | 1991 | All patients who received cardiac catheterization in the outpatient laboratory over a 3-year period. Patients were selected for outpatient catheterization if they were ambulatory and symptoms were not unstable. | Recent MI, congestive heart failure, and advanced age were considered general contraindications.
Kern et al.(28) | 1990 | All patients undergoing diagnostic left heart catheterization and selective coronary arteriography who were discharged in ≤23 hr after admission in 5 medical centers over a 7-month period. | Patients were excluded if they required continued heparin and arterial sheath placement before either angioplasty or coronary artery bypass surgery, or if they required use of 7F or 8F catheters because of unusually difficult 5F catheter placement or suboptimal angiograms, or both.
Murray and Rothman(29) | 1989 | All patients planned as day cases over an 11-month period. Patients were considered suitable as day cases if their medical condition was stable, if there was no prolonged period of assessment or treatment planned as an inpatient and if there was no problem in travelling to and from the hospital the same day. | If any of the inclusion criteria were not fulfilled or if a femoral approach to catheterization was planned.
Oldroyd et al.(30) | 1989 | All patients who received outpatient catheterization performed by the modified Judkins technique over a 3-year period. | None stated
Pink et al.(31) | 1989 | All patients who received outpatient catheterization over a 41-month period. Patients of any age were accepted if they were clinically stable and free from serious non-cardiac disease. | Patients with unstable coronary syndrome, uncompensated congestive heart failure, serious ventricular arrhythmia, or any other indication of hemodynamic or electrical instability were excluded from the outpatient lab.
Block et al.(21) | 1988 | Patients scheduled for routine cardiac catheterization with the clinical diagnosis of coronary artery disease, valvular disease, or congenital heart disease. | Patients were excluded if they were over age 70 (women) or age 75 (men), or if they had any of the following conditions: unstable angina pectoris, valvular heart disease with congestive heart failure, bleeding diasthesis, renal insufficiency with a blood urea nitrogen level of >10.7 mmol per liter (30 mg/dl) or a creatinine concentration of >176.8 μmol/l (2 mg/dl), or uncontrolled systolic hypertension (systolic blood pressure >180 mm Hg). Patients were also excluded if they lived >25 miles from the hospital unless they could stay overnight in nearby lodging.
Murdock et al.(32) | 1988 | All patients admitted for outpatient coronary angiography over a 22-month period. | Patients with NYHA functional grade 3 or 4, those with a high probability of proceeding to angioplasty at the same procedure and those who were already inpatients.
Mahrer et al.(33) | 1987 | All patients seen as elective outpatients over a 31-month period. Elective outpatients were those with stable coronary problems. | Not stated
Fighali et al.(34) | 1985 | All patients who received outpatient catheterization at the same institution over a 33-month period. Specific criteria for selecting outpatients was not stated. | Patients who were in NYHA functional class 4 in spite of optimal medical management and patients who preferred to be hospitalized for the catheterization procedure.
Klinke et al.(35) | 1985 | All outpatient cardiac catheterizations performed at the same institution over a 66-month period. Specific criteria for selecting outpatients was not stated, although the authors stated that criteria was up to the individual cardiologist. | Patients already hospitalized because of cardiovascular disease-related complications such as unstable angina, MI or congestive heart failure.
Fierens(36) | 1984 | NR | NR
Gavin et al.(39) | 1981 | Consecutive outpatients. Requirements for outpatient catheterization were not stated. | Patients with an identified surgical lesion were selected for inpatient catheterization.
Mahrer and Eshoo(38) | 1981 | All consecutive outpatients. Patients were considered for outpatient study if they did not meet any of the specific exclusion criteria. | Patients with unstable symptoms, history of recent congestive heart failure, history of life-threatening arrhythmias, severe valvular disease, or associated illnesses such as insulin-dependent diabetes, severe chronic obstructive pulmonary disease (COPD), or steroid dependency were excluded from outpatient study.
Oehlert(40) | 1981 | Consecutive outpatients. All were required to be clinically stable | Not stated

a Two separate series of patients in freestanding settings were reported in this article. This series was retrospective.

b Two separate series of patients in freestanding settings were reported in this article. This series was prospective.

NR – Not reported

Table C-2 Characteristics of Patients Receiving Diagnostic Cardiac Catheterization

Author/ year | Care setting | N | Age (mean ±SD) | % female | % prior catheterization | % prior PTCA | % prior CABG | % prior MI | % diabetes | % peripheral vascular disease | % hypertension | % COPD | % current smokers | % CHF | % angina | % history of cholesterol ≥240 mg/dl
Jackson 1989(12)^a^ | Freestanding clinic | 12472 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Jackson 1989(12)^b^ | Freestanding clinic | 4512 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Diethrich et al. 1981(37) | Freestanding clinic | 254 | 60 (range 29 to 79) | 17.7 | 27 | NR | NR | 42.5 | 11.4 | NR | 35 | NR | 24 | 4.3 | NR | NR
Baird 1980(42) | Freestanding clinic | 620 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Perrigo et al. 1981(41) | Freestanding clinic | 224 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Akdemir et al. 2004(22) | Hospital outpatient (mobile) | 1485 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Peterson and Peterson 2004(23) | Hospital outpatient (mobile) | 1775 | 58.5 (range 27 to 90) | 39.5 | NR | 11 (PTCA or CABG) | See PTCA | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bersin et al. 1994(24) | Hospital outpatient (mobile) | 1001 | Range 22 to 84 | 43.6 | NR | NR | NR | NR | NR | NR | NR | NR | NR | 7.1 | 46.4 | NR
Elliott et al. 1994(25) | Hospital outpatient | 277 | 61 (range 29 to 88) | 33.6 | NR | NR | NR | NR | NR | NR | NR | NR | NR | 13.4 | NR | NR
Clark and Dolce 1993(26) | Hospital outpatient | 847 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Clements Jr. and Gatlin 1991(27) | Hospital outpatient^c^ | 3000 | NR | NR | NR | NR | 13 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kern et al. 1990(28) | Hospital outpatient | 287 | 58 (range 25 to 91) | 42 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Murray and Rothman 1989(29) | Hospital outpatient | 855 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Oldroyd et al. 1989(30) | Hospital outpatient | 900 | 54 (range 18 to 76) | 20 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Pink et al. 1989(31) | Hospital outpatient | 1000 | Range 23 to 84 | 21.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Block et al. 1988(21) | Hospital outpatient | 192 | 55.7 | 18.2 | NR | NR | 10.9 | 35.9 | 2.6 | NR | 34.4 | NR | NR | NR | 62 | NR
Murdock et al. 1988(32) | Hospital outpatient | 1398 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mahrer et al. 1987(33) | Hospital outpatient | 2011 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fighali et al. 1985(34) | Hospital outpatient | 676 | 59 (range 16 to 76) | 32 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Klinke et al. 1985(35) | Hospital outpatient | 3071 | NR | 26 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fierens 1984(36) | Hospital outpatient | 5107 | Range 14 to 86 | 30 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Gavin et al. 1981(39) | Hospital outpatient | >100 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mahrer and Eshoo 1981(38) | Hospital outpatient | 308 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Oehlert 1981(40) | Hospital outpatient | 100 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

a Two separate series of patients in freestanding settings were reported in this article. This series was retrospective.

b Two separate series of patients in freestanding settings were reported in this article. This series was prospective.

c Outpatient diagnostic cardiac catheterizations are performed in a building across the street from the hospital. However, the building is connected to the hospital by an underground tunnel, so it does not fit the ACC/AHA definition of a freestanding catheterization facility (which is not physically connected to a hospital).

NR – Not reported

Table C-3 Additional Characteristics of Patients Receiving Diagnostic Cardiac Catheterization

Author/ year | Care setting | N | Age (mean ±SD) | % female | % >50% left main stenosis | % three-vessel disease | % two-vessel disease | % single-vessel disease | % mild CAD (lesions ≤50%) | % normal angiogram | % valvular disease | % cardiomyopathy | % left ventricular hypertrophy | % congenital disease
Jackson 1989(12)^a^ | Freestanding clinic | 12472 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Jackson 1989(12)^b^ | Freestanding clinic | 4512 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Diethrich et al. 1981(37) | Freestanding clinic | 254 | 60 (range 29 to 79) | 17.7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Baird 1980(42) | Freestanding clinic | 620 | NR | NR | Ischemic heart disease 59% (not broken down into subcategories) | | | | | 28.9 | 9.5 | 1.3 | NR | 0.6
Perrigo et al. 1981(41) | Freestanding clinic | 224 | NR | NR | Significant coronary artery disease 53% (not broken down into subcategories) | | | | NR | NR | 14 | 4 | NR | 4
Akdemir et al. 2004(22) | Hospital outpatient (mobile) | 1485 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Peterson and Peterson 2004(23) | Hospital outpatient (mobile) | 1775 | 58.5 (range 27 to 90) | 39.5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Bersin et al. 1994(24) | Hospital outpatient (mobile) | 1001 | Range 22 to 84 | 43.6 | 4.7 | 18 | 16 | 19.7 | 13.6 | 22.8 | 4.3 | 13.3 (cardiomyopathy or LVH) | See cardiomyopathy | NR
Elliott et al. 1994(25) | Hospital outpatient | 277 | 61 (range 29 to 88) | 33.6 | 6.9 | 22 | 17.7 | 26 | 9.7 | 12.4 | 10.1 | NR | 4 | NR
Clark and Dolce 1993(26) | Hospital outpatient | 847 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Clements Jr. and Gatlin 1991(27) | Hospital outpatient^c^ | 3000 | NR | NR | 2.2 | 10.8 | 16 | 23.5 | 8.6 | 23.5 | 2 | NR | NR | NR
Kern et al. 1990(28) | Hospital outpatient | 287 | 58 (range 25 to 91) | 42 | NR | 20 | 22 | 24 | NR | 33 | NR | 11 | NR | NR
Murray and Rothman 1989(29) | Hospital outpatient | 855 | NR | NR | NR | NR | NR | NR | NR | 9 | 9 | NR | NR | NR
Oldroyd et al. 1989(30) | Hospital outpatient | 900 | 54 (range 18 to 76) | 20 | 6.2 | 37.9 | 22 | 16.1 | NR | 17.8 | 17 | 5 | NR | 0.8
Pink et al. 1989(31) | Hospital outpatient | 1000 | Range 23 to 84 | 21.5 | 6.8 | 33 | 22.5 | 33 | NR | 11.5 | 2 | 0.7 | NR | 0
Block et al. 1988(21) | Hospital outpatient | 192 | 55.7 | 18.2 | 5.2 | 34.4 | 25.5 | 21.9 | NR | NR | 3.7 | NR | NR | NR
Murdock et al. 1988(32) | Hospital outpatient | 1398 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mahrer et al. 1987(33) | Hospital outpatient | 2011 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Fighali et al. 1985(34) | Hospital outpatient | 676 | 59 (range 16 to 76) | 32 | 5 | 30 | 16 | 14 | NR | 12 | 15 | 4 | NR | 2
Klinke et al. 1985(35) | Hospital outpatient | 3071 | NR | 26 | 5 | 27 | 32 | 36 | NR | 13.6 | 12.5 | 3.5 (cardiomyopathy or congenital) | NR | See cardiomyopathy
Fierens 1984(36) | Hospital outpatient | 5107 | Range 14 to 86 | 30 | Coronary artery disease 61% (not broken down into subcategories) | | | | | 16.5 | NR | 2.8 | NR | NR
Gavin et al. 1981(39) | Hospital outpatient | >100 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mahrer and Eshoo 1981(38) | Hospital outpatient | 308 | NR | NR | 14.6 | 27.6 | 22 | 9.7 | NR | 16.3 | 2.6 | NR | NR | 6.8
Oehlert 1981(40) | Hospital outpatient | 100 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

a Two separate series of patients in freestanding settings were reported in this article. This series was retrospective.

b Two separate series of patients in freestanding settings were reported in this article. This series was prospective.

c Outpatient diagnostic cardiac catheterizations are performed in a building across the street from the hospital. However, the building is connected to the hospital by an underground tunnel, so it does not fit the ACC/AHA definition of a freestanding catheterization facility (which is not physically connected to a hospital).

NR – Not reported

Table C-4 Adverse Events Related to Diagnostic Catheterization (Freestanding Clinic and Hospital Outpatient)

Author/ year | Care setting | Length of followup | N | % death | % MI | % stroke/TIA | % pulmonary edema | % coronary dissection | % embolism | % accelerated angina | % ventricular fibrillation | % ventricular tachycardia | % bradycardia/hypotension/ vasovagal reaction | % allergic reaction | % bleeding/hematoma | % arterial thrombosis/ loss of radial pulse | % pseudoaneurysm | % other complications
Jackson 1989(12)^a^ | Freestanding clinic | NR | 12472 | 0.03 | 0.05 | 0.03 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Jackson 1989(12)^b^ | Freestanding clinic | NR | 4512 | 0 | 0 | 0.02 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Diethrich et al. 1981(37) | Freestanding clinic | NR | 254 | 0 | 0 | 0 | 0 | 0 | 0 | 0.4 | 0.4 | NR | 0.4 | 0.4 | 3.1 | 0 | 0 | Numbness 1.2 Nausea 0.8 Pain 2.0
Baird 1980(42) | Freestanding clinic | NR | 620 | 0.16 | 0.16 | 0 | 0 | 0.16 | 0.16 | NR | NR | 0.16 | NR | NR | NR | 2.0 | NR | Knotted catheter 0.16
Perrigo et al. 1981(41) (abstract) | Freestanding clinic | NR | 224 | 0 | 0 | 0 | 0 | 0 | 0 | NR | 1.8 (arrhythmias) | | NR | NR | NR | 0.9 | NR | NR
Akdemir et al. 2004(22) | Hospital outpatient (mobile) | NR | 1485 | 0 | 0 | 0.1 | 0 | 0 | 0 | NR | NR | NR | NR | 0 | NR | NR | 0.1 | NR
Peterson and Peterson 2004(23) | Hospital outpatient (mobile) | NR | 1775 | 0 | 0.06 | 0.06 | 0 | 0 | 0 | 0.2 | 0 | 0.06 | 0.06 | 0.2 | 0.2 | NR | NR | Decreased peripheral pulse 0.06 Catheter problem 0.06 Other 0.1
Bersin et al. 1994(24) | Hospital outpatient (mobile) | 1 day | 1001 | 0 | 0.3 | 0.1 | 0 | 0 | 0 | 0 | 0 | 0.1 | 0.1 | 0.2 | 0.3 | 0 | 0.1 | 0
Elliott et al. 1994(25) | Hospital outpatient | 1 day | 277 | 0 | 0.36 | 0 | 0 | 0 | 0 | 0.72 | 0 | 0 | 0 | 0.36 | 0 | 0 | 0 | 0
Clark and Dolce 1993(26) | Hospital outpatient | NR | 847 | 0 | 0 | 0.1 | 0 | 0 | 0 | NR | NR | 0.2 | 0.1 | NR | 0.2 | 0.1 | NR | NR
Clements Jr. and Gatlin 1991(27) | Hospital outpatient^c^ | 1 day | 3000 | 0 | 0 | 0.07 | 0.07 | 0 | 0 | 0 | 0.2 | 0 | 0 | 0.07 | 0.1 | 0 | 0.1 | Emergency PTCA 0.3 Peripheral nerve injury 0.3 Infection 0.3
Kern et al. 1990(28) | Hospital outpatient | 1 to 3 days | 287 | 0 | 0 | 0.3 | 0 | 0 | 0 | 0 | 0 | 0.7 | 0 | 0 | 7.0 | 0 | 0 | 0
Murray and Rothman 1989(29) | Hospital outpatient | NR | 855 | 0 | 0 | NR | NR | NR | NR | 1.0 | 0 | 0 | 0.2 | NR | 0.4 | 0.2 | NR | NR
Oldroyd et al. 1989(30) | Hospital outpatient | NR | 900 | 0.2 | 0.7 | 0.1 | 0.3 | 0.7 | 0.1 | 1.1 | 0.1 | 0 | 0.3 | 0.2 | 0.6 | 0 | 0.1 | 0
Pink et al. 1989(31) | Hospital outpatient | 1 day | 1000 | 0 | 0.2 | 0.4 | 0 | 0.1 | 0 | 0.9 (unstable) | 0.4 (VF or VT) | | 0.1 | 0.3 | 1.5 | 0.1 | 0.1 | Congestive heart failure 0.1
Block et al. 1988(21) | Hospital outpatient | 7 days | 192 | 0 | 1.6 | 0 | 0 | 0 | 0 | 1.6 | NR | NR | 0.5 | 0.5 | 12 | 0.5 | 0 | Numbness/weakness of extremity 0.5 Cold or blue extremity 1.6
Murdock et al. 1988(32) | Hospital outpatient | Up to 1 day | 1398 | 0 | 0 | 0.3 | 0 | 0 | 0 | 0.9 (developed before procedure) | 0.14 | 0 | NR | NR | 2.9 | 0.3 | 0 | Ruptured pulmonary artery during Swan-Ganz catheterization 0.07
Mahrer et al. 1987(33) | Hospital outpatient | 7 to 14 days | 2011 | 0.05 | 0.05 | 0.05 | NR | NR | NR | NR | 0.6 | NR | NR | NR | 0 | Vascular complications 0.15 | | Other (unspecified) 0.05
Fighali et al. 1985(34) | Hospital outpatient | 1 day | 676 | 0 | 0 | 0 | 0 | 0 | 0 | 0.4 | 0 | 0 | 0 | 0.1 | 0 | 0.4 | 0 | 0
Klinke et al. 1985(35) | Hospital outpatient | Up to 30 days | 3071 | 0.13 | 0.07 | 0.14 | 0 | 0 | 0.03 | NR | 0.26 (VF or VT) | | 0.16 | NR | NR | Vascular complications 0.35 | | NR
Fierens 1984(36) | Hospital outpatient | NR | 5107 | 0 | 0 | 0.02 | 0 | 0 | 0 | NR | 0.14 | NR | NR | 0.02 | NR | 2.0 | NR | NR
Gavin et al. 1981(39) | Hospital outpatient | NR | >100 | 0 | 0 | 0 | 0 | 0 | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mahrer and Eshoo 1981(38) | Hospital outpatient | 7 to 14 days | 308 | 0.3 | 0.6 | 0 | 0 | 0 | 0.3 | NR | NR | NR | NR | NR | 0.6 | NR | NR | NR
Oehlert 1981(40) | Hospital outpatient | NR | 100 | 0 | 0 | 0 | 0 | 0 | 0 | NR | 1.0 | NR | NR | NR | NR | NR | NR | NR

a Two separate series of patients in freestanding settings were reported in this article. This series was retrospective.

b Two separate series of patients in freestanding settings were reported in this article. This series was prospective.

c Outpatient diagnostic cardiac catheterizations are performed in a building across the street from the hospital. However, the building is connected to the hospital by an underground tunnel, so it does not fit the ACC/AHA definition of a freestanding catheterization facility (which is not physically connected to a hospital).

NR – Not reported