# Excluded Studies

Table B-1 Excluded Studies

Reference | Year | Reason for exclusion
Key Question 1
Chandrasekar et al.(67) | 2001 | Inpatient and outpatient complications not reported separately
Lee et al.(68) | 1990 | Inpatient and outpatient complications not reported separately
Johnson et al.(44) | 1989 | Inpatient and outpatient complications not reported separately
Beauchamp(69) | 1981 | No quantitative statement (number or rate of complications not reported)
Schneider(70) | 1977 | No quantitative statement (number or rate of complications not reported)
Key Question 3
Alter et al.(71) | 2003 | Combined results for all treatments (PCI, CABG and thrombolysis)
Blondheim et al.(72) | 2001 | Combined results for all treatments (PCI, CABG and thrombolysis)
Rogers et al.(73) | 2000 | Combined results for all treatments (PCI, CABG and thrombolysis)
Every et al.(74) | 1997 | Combined results for all treatments (PCI, CABG and thrombolysis)
Bonzel et al.(75) (abstract) | 1994 | No quantitative statement regarding complications
Weaver et al.(76) | 1993 | Earlier results of included study(51)
Meier et al.(77) | 1992 | Patients were allocated to surgical standby or no surgical standby at a hospital with a cardiac surgery department. Since patients were selected for surgical standby based on specific characteristics that other patients (in the no surgical standby group) lacked, the comparison has a high potential for bias that could confound the comparison.
Key Question 4^a^
Akdemir et al.(22) | 2004 | Insufficient information on patient inclusion/exclusion criteria
Clark and Dolce(26) | 1993 | Insufficient information on patient inclusion/exclusion criteria
Jackson(12)^b^ | 1989 | Insufficient information on patient inclusion/exclusion criteria
Jackson(12)^c^ | 1989 | Insufficient information on patient inclusion/exclusion criteria
Oldroyd et al.(30) | 1989 | Insufficient information on patient inclusion/exclusion criteria
Fierens(36) | 1984 | Insufficient information on patient inclusion/exclusion criteria
Perrigo et al.(41) (abstract) | 1981 | Insufficient information on patient inclusion/exclusion criteria

a All studies excluded for Key Question 1 were also excluded for Key Question 4. To avoid redundancy, we have not listed them twice.

b Two separate series of patients in freestanding settings were reported in this article. This series was retrospective.

c Two separate series of patients in freestanding settings were reported in this article. This series was prospective.