# Literature Searches

The clinical studies included in this report were identified using the algorithm shown in Figure A-1. The first stage of this multi-staged study selection process consisted of a comprehensive literature search. The second stage of the process consisted of the retrieval of all articles that met a set of a priori retrieval criteria. The final stage of the study selection algorithm consisted of the selection of the actual studies that form the evidence base for this report using a set of a priori inclusion criteria.

Figure A-1 Study Selection Algorithm

Figure A-1. Study Selection Algorithm

## Electronic Database Searches

To obtain information for this report, we searched the following databases for relevant information:

PubMed

Several searches were conducted in PubMed to answer the different questions posed by CMS. Searches were not limited by year; retrieval was restricted to English language; fields are “all fields” unless otherwise noted.

Search 1: Questions 1 & 2 : do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for diagnostic/interventional procedures?

1. heart catheterization OR cardiac catheterization
2. heart diseases/su[mh] OR heart diseases/th[mh] OR percutaneous transluminal coronary angioplasty OR ptca OR coronary angioplasty OR cardiac angioplasty OR coronary atherectomy OR intracoronary thrombectomy OR angioplasty, transluminal, percutaneous coronary[mh] OR atherectomy, coronary[mh]
3. heart diseases/di[mh] OR coronary angiography
4. adverse events[sh] OR complications OR safety OR quality of health care OR treatment outcome
5. laboratories OR freestanding OR outpatient clinics, hospital[mh] OR ambulatory care facilities OR outpatient clinic* OR mobile health units
6. #1 OR #2 OR #3
7. #6 AND #4 AND #5
8. hospital units[mh] OR hospitals[mh] OR hospitalization[mh] OR operating room* OR surgical back-up
9. #7 AND #8
10. #1 AND #5 AND comparative study
11. (cardiac catheterization laborator* AND #4) NOT case reports[pt]
12. (#7 OR #11) AND (quality of health care OR treatment outcome)
13. (#1 OR #2) AND #4 AND (evidence-based medicine[mh] OR follow-up studies[mh] OR cross-sectional studies[mh]) AND (#8 OR #5)

Search 2: Question 3: Can interventional catheterization procedures be performed with comparable complication rates at hospitals with and without surgical back-up?

1. c-port OR atlantic cardiovascular patient outcomes research team OR pamino sos
2. percutaneous coronary intervention* OR pci OR cardiac angioplast* OR coronary angioplast* OR heart angioplast* OR rotational atherectom* OR directional coronary atherectom* OR ptca
3. extraction atherectom* OR laser angioplast* OR intracoronary stent*
4. angio, transluminal, percutaneous coronary[mh] OR coronary artery bypass[mh] OR atherectomy, coronary[mh] OR angioplasty, laser[mh] OR coronary arteriosclerosis/th[mh] OR coronary arteriosclerosis/su[mh]
5. #2 OR #3 OR #4
6. surgery OR surgical
7. backup OR back-up OR onsite OR on-site OR stand-by OR standby
8. #5 AND #6 AND #7
9. #8 NOT (editorial[pt] OR letter[pt] OR case reports[pt]
10. cardiology service, hospital[mh] AND #7 AND #6
11. Prague-2 AND clinical trial*
12. (#2 OR myocardial infarction) AND (transport* OR patient transfer)

Search 3: Question 4: patient characteristics.

1. heart diseases/su[mh] OR heart diseases/th[mh] OR percutaneous transluminal coronary angioplasty OR ptca OR coronary angioplasty OR cardiac angioplasty OR heart angioplasty OR angioplasty, transluminal, percutaneous coronary[mh]
2. coronary atherectomy OR cardiac atherectomy OR heart atherectomy OR intracoronary thrombectomy OR atherectomy, coronary[mh]
3. cardiac electrophysiology OR coronary angiography OR heart angiography OR cardiac angiography OR echocardiography
4. patient selection[mh] OR outcome assessment (health care)[mh] OR prognostic factors OR survival analysis[mh] OR patient characteristics
5. laboratories OR freestanding OR outpatient clinics, hospital[mh] OR ambulatory care facilities OR outpatient clinic* OR mobile health units OR stand-alone OR cardiac catheterization laborator* OR cath lab*
6. heart catheterization OR cardiac catheterization
7. #1 OR #2 OR #3 OR #6
8. #4 AND #7 AND #5
9. #8 NOT (letter[pt] OR editorial[pt] OR case reports[pt])
10. #7 AND (#5 OR cardiology service, hospital[mh]) AND (patient selection[mh] OR health services accessibility[mh])
11. #5 OR cardiology service, hospital[mh] OR cardiac care facilities
12. #11 AND #7 AND #4
13. #12 AND (comparative study OR health services accessibility[mh])
14. #7 AND utilization[sh]
15. #14 AND #11
16. #7 AND #11 AND comparative study
17. #16 NOT (letter[pt] OR editorial[pt] OR case reports[pt])
18. #7 AND (cath lab*[tw] OR catheterization lab*[tw])
19. #18 AND comparative study
20. #18 AND #4

Search 4: Guidelines and standards for cardiac catheterization procedures.

1. consensus development conferences[mh] OR consensus development conference[pt] OR consensus development conference, nih[pt]
2. #1 OR standards[sh] OR guideline[pt] OR practice guideline[pt] OR guidelines[mh]
3. heart catheterization OR cardiac catheterization
4. #3 AND #2
5. heart diseases/su[mh] OR heart diseases/th[mh] OR percutaneous transluminal coronary angioplasty OR ptca OR coronary angioplasty OR cardiac angioplasty OR angioplasty, transluminal, percutaneous coronary[mh] OR coronary atherectomy OR intracoronary thrombectomy OR atherectomy, coronary[mh] cardiac electrophysiolog* OR intracardiac echocardiography
6. #5 AND #2
7. (#5 OR #3) AND (guideline* OR standard* OR consensus OR “position paper”) AND (in process[sb] OR publisher[sb])
8. cath lab* OR (#3 AND laborator* OR freestanding OR ourpatient clinics, hospital[mh] OR ambulatory care facilities OR outpatient clinic* OR mobile health units)
9. #8 AND (guideline* OR standarad* OR consensus OR “position paper”)
10. #9 AND (united states OR Canada OR great Britain)
11. #8 AND facility regulation and control[mh]

Cath Lab Digest (serial not indexed in PubMed) Searched publication Web site using the following terms:

1. surgical back-up
2. surgical support
3. clinical trials AND back-up
4. c-port
5. freestanding
6. mobile
7. cardiac surgery
8. regulations

National Institute for Clinical Excellence (NICE)

- Catheterization [Web site search]
- Catheterization [interventional procedures search]
- Any[disease] AND cardiology[speciality] AND any[status] [interventional procedures search]

Canadian Coordinating Office for Health Technology Assessment (CCOHTA)

- Catheterization

National Guideline Clearinghouse (NGC)

- Catheterization AND diagnostic tool
- Catheterization AND therapeutic tool
- Freestanding AND “cardiac catheterization”
- Freestanding AND “heart catheterization”
- Cath lab*
- “cardiac catheterization”[kw] AND diagnosis[category] AND cardiology[clinical speciality]
- “cardiac catheterization”[kw] AND treatment[category] AND cardiology[clinical speciality]

Healthcare Standards Directory online (ECRI)

- Cardiac catheterization laboratories[kw]
- “cardiac catheterization” AND (clinic* OR free*)
- “heart catheterization” AND (clinic* OR free*)
- percutaneous transluminal coronary angioplasty[kw]
- atherectomy AND “coronary artery disease”
- cardiac catheterization[kw]
- cardiac catheters[kw]
- cardiac diagnostic facilities[kw]
- electrophysiology AND (cardiac OR coronary OR heart OR coronary)
- coronary angiography[kw]
- echocardiography[kw]
- “vascular stents” AND (coronary OR cardiac OR heart OR “peripheral artery” OR cardiology)
- angioplasty AND (coronary OR intracoronary OR cardiac OR heart OR cardiology)
- catheter ablative procedures[kw]

Joint Commission for Accreditation of Healthcare Organizations (JCAHO)

Catheterization (JCAHO standards are in the Comprehensive Accreditation Manual for Ambulatory Care)

Medscape

Content type – conference coverage.

- “onsite surgical” OR “surgical standby” OR “surgical support” OR “surgical backup” OR “onsite surgery” OR surgery standby OR surgery support OR surgery backup
- (cardiac OR heart) AND (surgery or surgical) AND (onsite OR on-site OR standby OR stand-by OR backup OR back-up)
- (ptca OR coronary angioplasty OR coronary interventions OR pci) AND (onsite OR on-site OR standby OR stand-by OR backup OR back-up)
- c-port
- pami no-sos
- Prague-2

Cochrane

1. Heart catheterization OR cardiac catheterization
2. Freestanding OR stand-alone OR mobile OR ambulatory OR outpatient
3. #1 AND #2
4. angioplasty OR pci OR percutaneous coronary intervention*
5. (on-site OR onsite OR standby OR stand-by OR backup OR back-up) AND (surgery OR surgical)
6. #4 AND #5
7. c-port OR Prague-2 OR pami no-sos

Google

- Cardiac catheterization meeting
- Heart catheterization meeting
- Cath lab meeting
- Cardiac catheterization surgical back-up
- Heart catheterization surgical back-up
- Cath lab surgical back-up
- c-port catheterization
- pami no-sos
- Prague-2 catheterization

LEXIS

- State Administrative Codes, combined
  - (Cardiac catheterization OR heart catheterization) w/5 (freestanding OR ambulatory OR mobile OR outpatient OR stand-alone)
  - (cardiac catheterization OR heart catheterization) AND freestanding
  - (heart OR cardiac) catheterization w/p (laborator! OR clinic!) w/p (mobile or freestanding OR ambulatory OR outpatient)
  - (heart OR cardiac) catheterization w/5 (freestanding OR ambulatory OR mobile) AND [heading] certificate of need
  - (laborator! OR clinic!) w/10 freestanding AND cardiac
  - cath lab AND (freestanding OR mobile)
- State codes, constitutions, court rules, combined
  - (cardiac OR heart) catheterization AND (freestanding OR stand-alone OR mobile OR ambulatory OR outpatient)
  - cath lab! AND (freestanding OR mobile OR stand-alone OR ambulatory OR outpatient)
- The following states were searched individually in Lexis because there was no retrieval in the combined search:
  - Idaho, Connecticut, Colorado, Indiana, Wyoming, Wisconsin, West Virginia, Washington, Utah, Texas, South Dakota, Oregon, Oklahoma, North Dakota, New York, New Mexico, New Hampshire, Nevada, Nebraska, Montana, Missouri, Michigan, Louisiana, Kansas.
- Search strategy:
  - (cardiac catheterization OR heart catheterization OR cath lab!) AND (freestanding OR mobile OR ambulatory OR outpatient) in administrative codes and statutes
- The following states were searched more broadly to retrieve additional information:
  - Alabama, Arkansas, Colorado, Florida, Georgia, Hawaii, Illinois, Kentucky, Maine, Minnesota, Missouri, New York, North Carolina, Rhode Island, South Carolina, Tennessee, West Virginia.
- Search strategy:
  - (heart OR cardiac) w/5 catheter! In Admininstrative codes and Statutes.

Because nothing was found in Lexis search for Colorado and Kentucky, these states were also searched in FindLaw.

EMBASE

The Medline search strategy was translated into Dialog search strategy so that duplicate citations could be removed. All searches were limited to English, human and 1980:2005.

Search 1: Questions 1 & 2 : do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for diagnostic/interventional procedures?

1. Heart()catheterization OR cardiac()catheterization OR intracoronary()thrombectomy OR transluminal coronary angioplasty/de OR (coronary OR heart OR cardiac)(2n)atherectomy OR angiocardiography/de OR heart electrophysiology/de OR echocardiography/de OR percutaneous coronary intervention/de OR intracoronary()stent? OR coronary()stent! OR coronary artery bypass graft/de OR angioplasty/de
2. Adverse()event? OR complication/de OR safety/de OR treatment outcome/de
3. (freestanding or outpatient or mobile or ambulatory)(3N)(clinic OR clinics OR facilit? OR laborat? OR center? OR unit?)
4. Dc=n1.10.400.400 OR operating()room? OR cardiology()service? OR (cardiac()care(3n)(facilit? OR unit?))
5. (1 AND 2) AND (3 OR 4)

Search 2: Question 3. Can PCIs be performed with comparable complication rates at hospitals with and without surgical back-up?

8. (surgery OR surgical)(3n)(backup OR back-up OR onsite OR on-site OR stand-by OR standby) OR patient(3n)(transfer or transport?)
9. 1 AND 8

Search 3: Question 4: patient characteristics

6. Patient()selection/de OR outcome()assessment OR prognostic()factors OR patient()characteristics

7. 1 AND 3 AND 6

Search 4: Guidelines and standards for cardiac catheterization procedures

10. Consensus development/de or practice guideline/maj OR practice()guideline/ti OR position()paper/ti
11. 1 AND 10

Dept. of Health, United Kingdom

Used all of the following strategies:

- (heart OR cardiac) AND catheter
- “cardiac catheter laboratories”
- Cardiac catherisation AND “policy guidance”
- Cath labs AND “policy guidance”

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature).