# SCOPE OF REPORT

The Centers for Medicare & Medicaid Services (CMS) requested that AHRQ commission an evidence report to assist in updating the CMS policy regarding cardiac catheterization in freestanding clinics. Accordingly, on February 9^th^ 2005, AHRQ issued a Statement of Work (SOW) contracting ECRI to prepare an evidence report on this topic. In commissioning this report, AHRQ, in consultation with CMS and ECRI, developed five Key Questions to be addressed. These questions are as follows:

1. Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for diagnostic catheterization procedures?
2. Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for interventional catheterization procedures?
3. Do hospitals without cardiac surgical support and hospitals with cardiac surgical support have comparable complication rates for diagnostic and interventional catheterization procedures? This question will only be addressed if the literature is insufficient for questions 1 and/or 2 for freestanding clinics.
4. What are the characteristics of patients who have had catheterization procedures in freestanding cardiac catheterization clinics vs. hospitals?
5. What are the current state regulations, Certificate of Need (CON) requirements, and oversight procedures for freestanding cardiac catheterization clinics? Include a table summarizing regulations from all 50 states. Include also a review of international regulations and guidelines; at a minimum include information from the U.K. and Canada.

The issues and procedures addressed in this report are similar to those addressed in the American College of Cardiology (ACC)/Society for Cardiac Angiography and Interventions Clinical Expert Consensus Document on Cardiac Catheterization Laboratory Standards.(1) Although catheterization labs have evolved over the years, the core diagnostic procedures remain cardiac catheterization and coronary angiography, which are the most widely performed diagnostic procedures in cardiac catheterization facilities (including freestanding clinics). For catheterization laboratories that perform interventional procedures, the major interventional procedures are percutaneous coronary interventions (PCI), including percutaneous transluminal coronary angioplasty (PTCA) and coronary stenting.

Other procedures, such as electrophysiologic studies (EPS), are beyond the scope of this report. EPS are catheter-based procedures that map induced or spontaneous tachyarrhythmias to investigate electrical activities in the heart. Although these procedures are performed in some catheterization facilities, they are performed in a separate EPS lab at many institutions. EPS represent a different area of clinical specialization, requiring a different skill set than that required for performance of core catheterization procedures. Diagnostic cardiac catheterization, coronary angiography, and PCI procedures are generally performed by invasive or interventional cardiologists, while EPS (and associated interventional procedures such as radiofrequency ablation) are generally performed by electrophysiologists.

Another limit in the scope of this report concerns the patient population. Pediatric patients were beyond the scope of this report for two reasons. First, cardiac catheterization procedures are not performed on pediatric patients in any setting except a hospital with pediatric cardiac surgery services. Second, this report is intended to be most relevant to the Medicare population.