# EXECUTIVE SUMMARY

The Centers for Medicare & Medicaid Services (CMS) requested that AHRQ commission an evidence report to assist in updating the CMS policy regarding cardiac catheterization in freestanding clinics. Accordingly, on February 9^th^ 2005, AHRQ issued a Statement of Work (SOW) contracting ECRI to prepare an evidence report on this topic. The SOW specified that ECRI undertake the following tasks in assembling this report:

1. Systematically search, review, and analyze the relevant scientific evidence for each question. Search MEDLINE and other suitable databases containing primary literature relevant to the questions to be addressed. Identify other sources of relevant literature, such as meeting abstracts, clinical trials currently in progress and clinical practice guidelines.
2. Retrieve and review full articles on eligible studies, assessing quality and extracting key data from each eligible study.
3. Prepare abbreviated evidence tables and summary of important findings.
4. Synthesis of data.

In commissioning this report, AHRQ, in consultation with CMS and ECRI, developed five Key Questions to be addressed. The findings of our assessment as they pertain to the five Key Questions are presented below.

## Key Question 1 Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for diagnostic catheterization procedures?

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified 23 publications that reported complication rates of diagnostic catheterization procedures in a freestanding or hospital outpatient setting. None of these studies directly compared complication rates in freestanding and hospital settings.

Thus, the quality of the evidence is low. The studies’ generalizability to the Medicare population was fair^1^.

1 High = Characteristics of all enrolled patients typical of Medicare population; Fair = Characteristics of some enrolled patients typical of Medicare population; Poor = Characteristics of only a few enrolled patients typical of Medicare population or enrolled patients represent a subgroup of Medicare population.

Five separate studies reported complications in a freestanding laboratory (two of these studies were reported only in a systematic review but have not been otherwise published). The mortality rates ranged from 0 to 0.16%, as did the rate of MI, while the rate of stroke/transient ischemic attack (TIA) ranged from 0 to 0.03%. Vascular complications ranged from 0 to 2.0%.

Nineteen studies reported complication rates in a mobile or fixed hospital outpatient setting. No deaths occurred in any of the three mobile laboratory studies, while the mortality rate ranged from 0 to 0.3% among the 16 fixed hospital outpatient studies. Rates of MI ranged from 0 to 0.1% in mobile labs and 0 to 0.7% in fixed outpatient settings, while rates of stroke/transient ischemic attack (TIA) ranged from 0 to 0.3% in mobile labs and 0 to 0.4% in fixed outpatient clinics. Rates of vascular complications ranged from 0 to 0.1% in mobile labs and 0 to 2.0% in fixed outpatient settings.

The available evidence did not reveal substantial differences in complication rates of diagnostic catheterization procedures among freestanding clinics and hospital outpatient settings. However, this indirect and informal comparison of low quality studies could not be risk-adjusted to compensate for differences in patient characteristics among the studies. Also, none of the freestanding clinic studies reported the length of followup; if it was shorter than the average followup in the hospital outpatient studies, this would create bias in the comparison. Furthermore, we cannot determine whether the relatively low complication rates reported in freestanding studies are generalizable to all freestanding centers, as this evidence base was susceptible to potential publication bias. Since all freestanding clinic studies and most hospital outpatient studies were published in the 1980s, the degree of relevance of the findings to current clinical practice is also unknown. These weaknesses in the evidence base mean that we cannot completely rule out the possibility of differences in complication rates between these settings.

## Key Question 2 Do freestanding cardiac catheterization clinics and hospitals have comparable complication rates for interventional catheterization procedures?

Our literature searches identified no studies that addressed this question. No evidence-based conclusion was possible regarding interventional catheterization procedures in freestanding centers. An American College of Cardiology (ACC)/Society for Cardiac Angiography and Interventions (SCAI) consensus document recommended that such procedures not be performed in freestanding settings, and we found no information to suggest that percutaneous coronary intervention (PCI) procedures are currently being performed in this setting.

## Key Question 3 Do hospitals without cardiac surgical support and hospitals with cardiac surgical support have comparable complication rates for diagnostic and interventional catheterization procedures? This question will only be addressed if the literature is insufficient for questions 1 and/or 2 for freestanding clinics

Because no evidence was available to address Key Question 2, we evaluated outcomes of PCI procedures at hospitals with and without surgical support. However, hospitals without cardiac surgical support are an imperfect surrogate for freestanding clinics, because even hospitals without cardiac surgical support have support services and resources beyond what is typically found in freestanding settings. Thus, one cannot be certain to what extent, if any, the findings for interventional procedures in a hospital setting can be extrapolated to a freestanding setting.

We identified seven retrospective controlled studies (five articles and two meeting abstracts) that compared complication rates of non-primary or primary PCI in hospitals with or without cardiac surgical support. These studies ranged from low to fair in quality based on U.S. Preventive Services Task Force (USPSTF) ratings. All were vulnerable to potential selection bias from lack of randomization and lack of followup of patients transferred to other hospitals. Generalizability to the Medicare population was fair except for one study where it was high.

Three studies of non-primary PCI (PCI for reasons other than emergent acute MI) reported conflicting results. One of these studies exclusively evaluated elective PCI procedures and found no statistically significant differences in complication rates between care settings. The remaining two studies evaluated all non-primary PCI procedures (including some emergent procedures). The only study that exclusively evaluated Medicare patients showed a significantly higher mortality rate in hospitals without cardiac surgical support, while the remaining study showed no significant difference between care settings. However, the latter study was low quality because no adjustments were made to account for baseline differences in the characteristics of patients who were seen at the differing hospital settings. Because these studies were vulnerable to selection bias and differed from each other in several characteristics, the conflicting results cannot be explained with certainty.

Six studies of primary PCI showed consistent findings of no statistically significant difference in rates of mortality or serious morbidity between hospitals with and without cardiac surgical backup. Three of the studies adjusted for differences in patient risk. However, all of these studies were vulnerable to selection bias to a greater or lesser degree, and some may have lacked adequate statistical power to detect a meaningful difference in rates. These flaws in the evidence base mean that failure to demonstrate a difference does not eliminate the possibility that a difference may exist.

## Key Question 4 What are the characteristics of patients who have had catheterization procedures in freestanding cardiac catheterization clinics vs. hospitals?

We found no studies that directly addressed this question, but 17 of 23 studies from Key Question 1 indirectly addressed the question through their patient inclusion/exclusion criteria. The quality of these studies was low, and their generalizability to the Medicare population was fair.

Two studies of freestanding facilities reported detailed inclusion/exclusion criteria, and these criteria were very similar to those reported in hospital outpatient studies. Both freestanding and hospital outpatient studies included clinically stable patients and excluded one or more subgroups of higher risk patients (with recent MI, Class IV cardiac disease, refractory unstable angina, and severe congestive heart failure, among others). Minor variability appeared in the specific subgroups of patients excluded among the different studies.

An ACC/SCAI expert consensus document recommended similar but slightly more stringent exclusion criteria for freestanding settings than for hospitals without cardiac surgical support. A published multivariable model for predicting complication risks during cardiac catheterization procedures is consistent with some of these recommendations.

## Key Question 5 What are the current state regulations, Certificate of Need (CON) requirements, and oversight procedures for freestanding cardiac catheterization clinics? Include a table summarizing regulations from all 50 states. Include also a review of international regulations and guidelines; at a minimum include information from the U.K. and Canada

Currently, 37 states (plus Washington, D.C.) do not prohibit diagnostic cardiac catheterization procedures in a freestanding setting. In these states, regulation usually occurs through certificate of need (CON) programs (16 states plus D.C.). Sixteen states without CON programs have no regulations or licensure requirements for such clinics. Sources in 13 states (plus D.C.) that do not prohibit freestanding catheterization services reported that there were no such facilities (or at least they were not aware of any) currently operating in these states.

Thirteen states have regulations prohibiting cardiac catheterization in freestanding clinics. In three of these states, pilot programs or regulatory loopholes have allowed at least one freestanding facility to perform cardiac catheterization procedures.

Any facility performing cardiac catheterization procedures can voluntarily seek Joint Commission on Accreditation of Healthcare Organizations (JCAHO) accreditation. The facility must meet several functional standards to gain accreditation.

Our survey of two other countries revealed that the United Kingdom does not allow any cardiac catheterization procedures to be performed outside of a hospital setting. Canada has no specific regulatory prohibitions on the national level, and four provinces did not report specific prohibitions, but all four provinces reported that no freestanding facilities were performing cardiac catheterization procedures. We cannot confirm whether any freestanding facilities perform these procedures in the remaining nine Canadian provinces and territories.