# BIBLIOGRAPHY

1 Bashore TM, Bates ER, Berger PB, Clark DA, Cusma JT, Dehmer GJ, Kern MJ, Laskey WK, O'Laughlin MP, Oesterle S, Popma JJ, O'Rourke RA, Abrams J, Bates ER, Brodie BR, Douglas PS, Gregoratos G, Hlatky MA, Hochman JS, Kaul S, Tracy CM, Waters DD, Winters WL Jr. American College of Cardiology/Society for Cardiac Angiography and Interventions Clinical Expert Consensus Document on cardiac catheterization laboratory standards. J Am Coll Cardiol. Jun. 15. 2001;37(8):2170-2214. [pmid: 11419904].
2 Olade R, Safi A, Kesari S. Cardiac catheterization (left heart). eMedicine [database online]. Omaha (NE). eMedicine.com, Inc. 1996. [updated 2002 Mar 21]. [cited 2004 Dec 16]. [14 p]. Available: http://www.emedicine.com/med/topic2958.htm.
3 Nissen SE, Yock P. Intravascular ultrasound: novel pathophysiological insights and current clinical applications. Circulation. Jan. 30. 2001;103(4):604-616. [pmid: 11157729].
4 Liu Z, McCormick D, Dairywala I, Surabhi S, Goldberg S, Turi Z, Vannan MA. Catheter-based intracardiac echocardiography in the interventional cardiac laboratory. Catheter Cardiovasc Interv. Sep. 2004;63(1):63-71. [pmid: 15343570].
5 Haugh R. The rise and uncertain future of cath labs. Hosp Health Netw. Sep. 2004;78(9):52-54. 56.
6 Popma JJ. (Director, Interventional Cardiology, Brigham & Women's Hospital. Associate Professor of Medicine, Harvard Medical School). Personal communication. Aug. 22. 2005:8.
7 Blankenship JC. Ethics in interventional cardiology: combining coronary intervention with diagnostic catheterization. Am Heart Hosp J. Winter. 2004;2(1):52-54. [pmid: 15604841].
8 Kimmel SE, Berlin JA, Hennessy S, Strom BL, Krone RJ, Laskey WK. Risk of major complications from coronary angioplasty performed immediately after diagnostic coronary angiography: results from the Registry of the Society for Cardiac Angiography and Interventions. J Am Coll Cardiol. Jul. 1997;30(1):193-200. [pmid: 9207642].
9 Health Technology Forecast [Technology profile]. Plymouth Meeting (PA). ECRI. 2004. updated 2004 Jan 28. [cited 2004 Dec 17]. Primary angioplasty. [6 p]. Available: http://www.ecri.org.
10 Sheldon WC. Trends in cardiac catheterization laboratories in the United States. Catheter Cardiovasc Interv. May. 2001;53(1):40-45. [pmid: 11329216].
11 Street Collins S. A Philadelphia story: cardiac catheterization center demonstrates out-of-the-box success. [internet]. Los Angeles (CA). CurAnt Communications Inc. 2004. Apr. cited 2004 Dec 20. [2 p].Available: http://www.imagingeconomics.com/library/tools/printengine.asp.
12 Jackson MN. Cardiac catheterization in a freestanding setting. Health Technol Assess Rep. 1989;(6):1-8. [pmid: 2696524].
13 Kahn KL. The efficacy of ambulatory cardiac catheterization in the hospital and free-standing setting. Am Heart J. Jan. 1986;111(1):152-167. [pmid: 3946142].
14 Pepine CJ, Allen HD, Bashore TM, Brinker JA, Cohn LH, Dillon JC, Hillis LD, Klocke FJ, Parmley WW, Ports TA, et al. ACC/AHA guidelines for cardiac catheterization and cardiac catheterization laboratories. American College of Cardiology/American Heart Association Ad Hoc Task Force on Cardiac Catheterization. Circulation. Nov. 1991;84(5):2213-2247. [pmid: 1934395].
15 Medicare coverage database. NCD for cardiac catheterization performed in other than a hospital setting (20.25). [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services. 1979. Aug. 1. cited 2004 Dec 14. [2 p]. Available: http://www.cms.hhs.gov/mcd/viewncd.asp?ncd_id=20.25.
16 Medicare coverage database. NCA tracking sheet for cardiac catheterization performed in other than a hospital setting (CAG-00166N). [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services. 2002. Oct. 8. cited 2004 Dec 14. [2 p]. Available: http://www.cms.hhs.gov/mcd/viewtrackingsheet.asp?id=15.
17 Pepine CJ, Babb JD, Brinker JA, Douglas JS Jr, Jacobs AK, Johnson WL Jr, Vetrovec GW. Guidelines for training in adult cardiovascular medicine. Core Cardiology Training Symposium (COCATS). Task Force 3: training in cardiac catheterization and interventional cardiology. J Am Coll Cardiol. Jan. 1995;25(1):14-16. [pmid: 7798492].
18 Smith SC Jr, Dove JT, Jacobs AK, Kennedy JW, Kereiakes D, Kern MJ, Kuntz RE, Popma JJ, Schaff HV, Williams DO, Gibbons RJ, Alpert JP, Eagle KA, Faxon DP, Fuster V, Gardner TJ, Gregoratos G, Russell RO, Smith SC Jr. ACC/AHA guidelines of percutaneous coronary interventions (revision of the 1993 PTCA guidelines)--executive summary. J Am Coll Cardiol. Jun. 15. 2001;37(8):2215-2239. [pmid: 11419905].
19 Johnson LA. Hospitals haggling over heart procedure. [internet]. Philadelphia (PA). Philadelphia Inquirer. 2004. Dec. 20. cited 2005 Apr 22. [2 p]. Available: http://www.philly.com/mld/inquirer/business/10456481.htm.
20 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, Atkins D. Current methods of the U.S. Preventive Services Task Force. A review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
21 Block PC, Ockene I, Goldberg RJ, Butterly J, Block EH, Degon C, Beiser A, Colton T. A prospective randomized trial of outpatient versus inpatient cardiac catheterization. N Engl J Med. Nov. 10. 1988;319(19):1251-1255. [pmid: 3185621].
22 Akdemir R, Ozhan H, Yazici M, Gunduz H, Erbilen E, Albayrak S, Uyan C. Three years of experience with a mobile angiograph in a center without on-site surgical back-up. Ann Saudi Med. Jul-Aug. 2004;24(4):253-258. [pmid: 15387488].
23 Peterson LF, Peterson LR. The safety of performing diagnostic cardiac catheterizations in a mobile catheterization laboratory at primary care hospitals. Angiology. Sep-Oct. 2004;55(5):499-506. [pmid: 15378112].
24 Bersin RM, Elliott CM, Elliott AV, Fedor JM, Gallagher JJ, Jordan L, Simonton CA 3rd, Svenson RH, Wilson BH, Zimmern SH. Mobile cardiac catheterization registry: report of the first 1,001 patients. Cathet Cardiovasc Diagn. Jan. 1994;31(1):1-7. [pmid: 8118851].
25 Elliott CM, Bersin RM, Elliott AV, Fedor JM, Gallagher JJ, Sellers LJ, Simonton CA, Svenson RH, Wilson BH, Zimmern SH. Mobile cardiac catheterization: comparison with outpatient and inpatient catheterization at tertiary facilities. Cathet Cardiovasc Diagn. Jan. 1994;31(1):8-15. [pmid: 8118864].
26 Clark VL, Dolce J. Unplanned admissions after outpatient cardiac catheterization. Clin Cardiol. Nov. 1993;16(11):823-826. [pmid: 8269661].
27 Clements SD Jr, Gatlin S. Outpatient cardiac catheterization: a report of 3,000 cases. Clin Cardiol. Jun. 1991;14(6):477-480. [pmid: 1810684].
28 Kern MJ, Cohen M, Talley JD, Litvack F, Serota H, Aguirre F, Deligonul U, Bashore TM. Early ambulation after 5 French diagnostic cardiac catheterization: results of a multicenter trial. J Am Coll Cardiol. Jun. 1990;15(7):1475-1483. [pmid: 2188985].
29 Murray NH, Rothman MT. Day case cardiac catheterisation using the Sones technique. Int J Cardiol. Jul. 1989;24(1):9-11. [pmid: 2759760].
30 Oldroyd KG, Phadke KV, Phillips R, Carson PH, Clarke M, Davis JA. Cardiac catheterisation by the Judkins technique as an outpatient procedure. BMJ. Apr. 1. 1989;298(6677):875-876. [pmid: 2497831].
31 Pink S, Fiutowski L, Gianelly RE. Outpatient cardiac catheterizations: analysis of patients requiring admission. Clin Cardiol. Jul. 1989;12(7):375-378. [pmid: 2743625].
32 Murdock CJ, Ireland MA, Davis MJ, Platell M. Day case cardiac catheterisation--a safe and economic alternative. Aust N Z J Med. Dec. 1988;18(7):833-835. [pmid: 3250405].
33 Mahrer PR, Young C, Magnusson PT. Efficacy and safety of outpatient cardiac catheterization. Cathet Cardiovasc Diagn. Sep-Oct. 1987;13(5):304-308. [pmid: 3664628].
34 Fighali S, Krajcer Z, Gonzales-Camid F, Warda M, Edelman S, Leachman R. Safety of outpatient cardiac catheterization. Chest. Sep. 1985;88(3):349-351. [pmid: 4028843].
35 Klinke WP, Kubac G, Talibi T, Lee SJ. Safety of outpatient cardiac catheterizations. Am J Cardiol. Oct. 1. 1985;56(10):639-641. [pmid: 4050701].
36 Fierens E. Outpatient coronary arteriography. Cathet Cardiovasc Diagn. 1984;10(1):27-32. [pmid: 6713532].
37 Diethrich EB, Kinard SA, Pierce SA, Koopot R. Outpatient cardiac catheterization and arteriography: Twenty-month experience at the Arizona Heart Institute. Cardiovasc Dis. Jun. 1981;8(2):195-204. [pmid: 15216207].
38 Mahrer PR, Eshoo N. Outpatient cardiac catheterization and coronary angiography. Cathet Cardiovasc Diagn. 1981;7(4):35560.
39 Gavin WA, Stewart DK, Murray JA. Outpatient coronary arteriography. Cathet Cardiovasc Diagn. 1981;7(4):347-348. [pmid: 7326731].
40 Oehlert WH. Outpatient coronary arteriography. J Okla State Med Assoc. Sep. 1981;74(9):314-315. [pmid: 7299511].
41 Perrigo ES, Kuehne ML, Michienzi F. 20 month experience in outpatient cardiac catheterization [abstract]. Am J Cardiol. Mar. 18. 1981;47:451.
42 Baird CL Jr. II. Ambulatory cardiac catheterization. Va Med. Sep. 1980;107(9):621-622. [pmid: 7210850].
43 Pryga EA. (Director, Policy. American Hospital Association). Personal communication. Aug. 29. 2005:8.
44 Johnson LW, Lozner EC, Johnson S, Krone R, Pichard AD, Vetrovec GW, Noto TJ. Coronary arteriography 1984–1987: a report of the Registry of the Society for Cardiac Angiography and Interventions. I. Results and complications. Cathet Cardiovasc Diagn. May. 1989;17(1):5-10. [pmid: 2720767].
45 Kutcher MA, Klein LW, Wharton TP, Applegate RJ, Brindis RG, Shaw RE, Weintraub WS. Clinical outcomes in coronary angioplasty centers with off-site versus on-site cardiac surgery capabilities: a preliminary report from the American College of Cardiology - National Cardiovascular Data Registry [abstract 852-1]. J Am Coll Cardiol. Mar. 3. 2004;43(5 Suppl 1):96A.
46 Sanborn TA, Jacobs AK, Frederick PD, Every NR, French WJ. Comparability of quality-of-care indicators for emergency coronary angioplasty in patients with acute myocardial infarction regardless of on-site cardiac surgery (report from the National Registry of Myocardial Infarction). Am J Cardiol. Jun. 1. 2004;93(11):1335-1339. A5. [pmid: 15165910].
47 Sanborn TA, Jacobs AK, Frederick PD, et al. Nationwide emergent coronary interventions (primary PCI) in patients with acute myocardial infarction in hospitals with and without on-site cardiac surgery: a report from the National Registry of Myocardial Infarction (NRMI) [abstract]. Circulation. 2002;106:II333.
48 Singh M, Ting HH, Gersh BJ, Berger PB, Lennon RJ, Holmes DR Jr, Garratt KN. Percutaneous coronary intervention for ST-segment and non-ST-segment elevation myocardial infarction at hospitals with and without on-site cardiac surgical capability. Mayo Clin Proc. Jun. 2004;79(6):738-744. [pmid: 15182087].
49 Wennberg DE, Lucas FL, Siewers AE, Kellett MA, Malenka DJ. Outcomes of percutaneous coronary interventions performed at centers without and with onsite coronary artery bypass graft surgery. JAMA. Oct. 27. 2004;292(16):1961-1968. [pmid: 15507581].
50 Wharton TP Jr, McNamara NS, Fedele FA, Jacobs MI, Gladstone AR, Funk EJ. Primary angioplasty for the treatment of acute myocardial infarction: experience at two community hospitals without cardiac surgery. J Am Coll Cardiol. Apr. 1999;33(5):1257-1265. [pmid: 10193725].
51 Weaver WD, Parsons L, Every N. Primary coronary angioplasty in hospitals with and without surgery backup. MITI project investigators. J Invasive Cardiol. Suppl F. 1995;7:34F-39F.
52 Garratt KN, Ting HT, Singh M, et al. Suported elective angioplasty procedures without on-site cardiac surgery is associated with low risk of adverse aevents. J Am Coll Cardiol. 2002;39(5 Suppl A):1028.
53 O'Neill WW, Brodie BR, Ivanhoe R, Knopf W, Taylor G, O'Keefe J, Grines CL, Weintraub R, Sickinger BG, Berdan LG, et al. Primary coronary angioplasty for acute myocardial infarction (the Primary Angioplasty Registry). Am J Cardiol. Apr. 1. 1994;73(9):627-634. [pmid: 8166056].
54 Laskey W, Boyle J, Johnson LW. Multivariable model for prediction of risk of significant complication during diagnostic cardiac catheterization. The Registry Committee of the Society for Cardiac Angiography & Interventions. Cathet Cardiovasc Diagn. Nov. 1993;30(3):185-190. [pmid: 8269487].
55 Calabria J. (Certificate of Need & Acute Care Licensing Program, Department of Health, Trenton, NJ). Personal communication. Apr. 14. 2005:2.
56 Dey SK. (Research and Innovation, American College of Cardiology, Bethesda MD). Personal communication. Apr. 6. 2005:3.
57 Norbut M. Cutting through the CONfusion: movement to relax the limits. [internet]. Chicago (IL). American Medical Association. 2005. Feb. 7. cited 2005 Mar 7. [5 p]. Available: http://www.ama-assoc.org/amednews/2005/02/07/bisa0207.htm.
58 American Health Planning Association (AHPA). National Directory of Health Planning, Policy and Regulatory Agencies. 16th ed. Falls Church (VA). American Health Planning Association (AHPA). Jan. 2005:107.
59 Joint Commission on Accreditation of Healthcare Organizations (JCAHO). [Web site]. Oakbrook Terrace (IL). Joint Commission on Accreditation of Healthcare Organizations (JCAHO). cited 2003 Oct 14. Available: http://www.jcaho.org.
60 Joint Commission on Accreditation of Healthcare Organizations (JCAHO). Comprehensive accreditation manual for ambulatory care 2005–2006 CAMAC. Oakbrook Terrace (IL). Joint Commission on Accreditation of Healthcare Organizations (JCAHO). 2005. 1 v. various pagings.
61 Pink GH, Montgomery C, Aird C, Vimr MA, Morgan CD. Developing guidelines for allocating catheterization laboratory resources: Lessons from an Ontario consensus panel. Can J Cardiol. Jan. 2000;16(1):49-57. [pmid: 10653934].
62 Edwards L. (Nova Scotia Department of Health, Halifax, Nova Scotia, Canada). Personal communication. May. 3. 2005:1.
63 Borowski H. (Program Service Division, Alberta Health and Wellness, Edmonton, Alberta, Canada). Personal communication. May. 3. 2005:1.
64 Mrozek TD. (Urban Regional Support Services, Manitoba Health, Canada). Personal communication. May. 4. 2005:1.
65 Porter B. (Saskatchewan Health, Regina, Saskatchewan, Canada). Personal communication. May. 16. 2005:2.
66 Giddy M. (Department of Health, United Kingdom). Personal communication. May. 4. 2005:1.
67 Chandrasekar B, Doucet S, Bilodeau L, Crepeau J, deGuise P, Gregoire J, Gallo R, Cote G, Bonan R, Joyal M, Gosselin G, Tanguay JF, Dyrda I, Bois M, Pasternac A. Complications of cardiac catheterization in the current era: a single-center experience. Catheter Cardiovasc Interv. Mar. 2001;52(3):289-295. [pmid: 11246238].
68 Lee JC, Bengtson JR, Lipscomb J, Bashore TM, Mark DB, Califf RM, Pryor DB, Hlatky MA. Feasibility and cost-saving potential of outpatient cardiac catheterization. J Am Coll Cardiol. Feb. 1990;15(2):378-384. [pmid: 2299080].
69 Beauchamp PK. Ambulatory cardiac catheterization cuts costs for hospital and patients. Hospitals. Apr. 16. 1981;55(8):62-63. [pmid: 6782007].
70 Schneider KW. The case for out-patient coronarography. Medicamundi. 1977;22(1):16-18.
71 Alter DA, Tu JV, Austin PC, Naylor CD. Waiting times, revascularization modality, and outcomes after acute myocardial infarction at hospitals with and without on-site revascularization facilities in Canada. J Am Coll Cardiol. Aug. 6. 2003;42(3):410-419. [pmid: 12906964].
72 Blondheim DS, Gottlieb S, Behar S, Marmor AT. Outcome of patients with post acute myocardial infarction ischemia hospitalized in intensive cardiac care units with and without on-site catheterization laboratories. Int J Cardiol. Jun. 2001;79(1):41-47. [pmid: 11399340].
73 Rogers WJ, Canto JG, Barron HV, Boscarino JA, Shoultz DA, Every NR. Treatment and outcome of myocardial infarction in hospitals with and without invasive capability. Investigators in the National Registry of Myocardial Infarction. J Am Coll Cardiol. Feb. 2000;35(2):371-379. [pmid: 10676683].
74 Every NR, Parsons LS, Fihn SD, Larson EB, Maynard C, Hallstrom AP, Martin JS, Weaver WD. Long-term outcome in acute myocardial infarction patients admitted to hospitals with and without on-site cardiac catheterization facilities. MITI Investigators. Myocardial Infarction Triage and Intervention. Circulation. Sep. 16. 1997;96(6):1770-1775. [pmid: 9323060].
75 Bonzel T, Neuhaus KL, Vogt A, et al. PTCA with and without in hospital surgical stanby in 12,965 patients. J Am Coll Cardiol. Suppl. 1994;23:223A.
76 Weaver WD, Litwin PE, Martin JS. Use of direct angioplasty for treatment of patients with acute myocardial infarction in hospitals with and without on-site cardiac surgery. The Myocardial Infarction, Triage, and Intervention Project Investigators. Circulation. Nov. 1993;88(5 Pt 1):2067-2075. [pmid: 8222100].
77 Meier B, Urban P, Dorsaz PA, Favre J. Surgical standby for coronary balloon angioplasty. JAMA. Aug. 12. 1992;268(6):741-745. [pmid: 1640573].
78 Sanders JE. (State Health Planning and Development Agency, Montgomery, AL). Personal communication. Apr. 14. 2005:1.
79 ALA. ADMIN. CODE r. 410-2-3-.03 (2004). Alabama state health plan 2004-2007. Chapter 410-2-3: Speciality services.
80 Pierce D. (Office of the Commissioner, Department of Health and Social Services, Juneau, Alaska). Personal communication. May. 24. 2005:1.
81 Golder L. (Arizona Department of Health Services, Phoenix, AZ). Personal communication. May. 6. 2005:1.
82 ARIZ. ADMIN. CODE § R9-10-115 (2004). Title 9: Health Services. Chapter 10. Department of Health Services: Health care institutions: licensing.
83 Gaskill J. (Health Facilities Services, Arkansas Department of Health. Little Rock, AR). Personal communication. Apr. 15. 2005:1.
84 CAL. HEALTH & SAFETY CODE § 100921-100922. Chapter 4. Regulation of laboratory services. Article 4. Freestanding cardiac catheterization laboratories.
85 Martone K. (Office of Health Care Access, Hartford, CT). Personal communication. May. 6. 2005:1.
86 Selassie A. (State Health Planning and Development Agency, Washington, DC). Personal communication. Apr. 14. 2005:1.
87 MyFloridaHealthStat: Glossary for facility information. [internet]. Tallahassee (FL). State of Florida. cited 2005 May 20. 2 p. Available: http://www.floridahealthstat.com/x-facilityglossary.shtml.
88 FLA. ADMIN. CODE 59C-1.032 (2005). Title 59. Agency for Health Care Administration Certificate of Need. Chapter 59C-1. Procedures for the administration of sections 408.031-408.045, Florida Statutes, Health Facility and Services Development Act.
89 GA. COMP. R & REGS. r.272-2-.09 (2004). Title 272: State Health Planning Agency Division of Health Planning. Chapter 272-2 Certificate of need. Section 09: Standards and criteria. Amended.
90 Sakamoto D. (State Health Planning and Development Agency. Honolulu, HI). Personal communication. Apr. 14. 2005:1.
91 Creswell S. (Bureau of Facility Standards, Idaho Department of Health and Welfare. Boise, ID). Personal communication. Apr. 18. 2005:1.
92 ILL. ADMIN. CODE tit. 77, § 205.135 (2005). Title 77: Public health. Part 205: Ambulatory surgical treatment center licensing requirements.
93 Ambulatory surgical centers' preliminary utilization report, Indiana, 2003. [internet]. Indianapolis (IN). Indiana State Department of Health. cited 2005 Apr 28. 2003:8. Available: http://www.in.gov/isdh/regsvcs/acc/asc/2003.htm.
94 Moore C. (Division of Health, Kansas Department of Health & Environment. Topeka, KS). Personal communication. May. 5–9. 2005:1.
95 Searles L. (Division of Health, Kansas Department of Health and Environment. Topeka, KS). Personal communication. May. 9. 2005:1.
96 Gray J. (Office of Certificate of Need, Cabinet of Health Services. Frankfort, KY). Personal communication. Apr. 14. 2005:1.
97 Pittman P. (Bureau of Health Services Financing, Baton Rouge, LA). Personal communication. May. 5. 2005:1.
98 Osgood D. (Department of Health and Human Services, Augusta, ME). Personal communication. May. 10. 2005:1.
99 MD. REGS. CODE 10 § 05.03.01 (2005). Code of Maryland Regulations. Title 10. Department of Health and Mental Hygiene. Subtitle 05. Freestanding ambulatory care facilities. Chapter 03. Freestanding major medical equipment facilities.
100 Piper TR. (Certificate of Need Program, Department of Health and Senior Services, Jefferson City, MO). Personal communication. Apr. 14. 2005:1.
101 Kemp R. (Licensure Bureau, Department of Public Health and Human Services, Helena, MT). Personal communication. Apr. 18. 2005:1.
102 Brown N. (Credentialing Division, Department of Health & Human Services, Lincoln, NE). Personal communication. Apr. 19. 2005:1.
103 Palm D. (Office of Public Health, Department of Health and Human Services, Lincoln, NE). Personal communication. Apr. 16. 2005:1.
104 Anspach J. (State Health Division, Carson City, NV). Personal communication. 5002 May 11. 1 p.
105 N.M. ADMIN CODE tit. 7 § 11.2.9 (2004). Title 7: Health. Chapter 11: Outpatient facilities. Part 2: Requirements for facilities providing outpatient medical services and infirmaries. Section 9: Types of facilities and scope of services.
106 Garland G. (Office of Community Assistance, Bismarck, ND). Personal communication. May. 4. 2005:1.
107 Hartsell HF Jr. (Health Resources Development Service, Oklahoma State Department of Health, Oklahoma City, OK). Personal communication. Apr. 18. 2005:1.
108 Smail K. (Health Care Licensure and Certification Section, Office of Public Health Systems, Portland, OR). Personal communication. Apr. 15. 2005:1.
109 Round L. (Rhode Island Department of Health, Providence, RI). Personal communication. May. 9. 2005:1.
110 Whiteside A. (Division of Planning & Certificate of Need, Department of Health & Environmental Control, Columbia, SC). Personal communication. Apr. 14. 2005:1.
111 Hill MM. (Tennessee Health Services and Development Agency, Nashville, TN). Personal communication. Apr. 15. 2005:2.
112 Stearman N. (Division for Regulatory Services, Texas Department State Health Services, Austin, TX). Personal communication. May. 2. 2005:1.
113 Nangle B. (Utah Department of Health, Salt Lake City, UT). Personal communication. Apr. 19. 2005:1.
114 12 VA. ADMIN. CODE § 5-260-40 (2004). Title 12. Health. Agency No. 5. Department of Health, Hospitals, Nursing Homes, and related institutions and services. Chapter 260. Cardiac services. Part II. Criteria and standards for cardiac catheterization services.
115 Bennett G. (Health Systems Quality Assurance, Department of Health, Washington). Personal communication. Apr. 18. 2005:1.
116 Barnhouse A. (Office of Health Facility Licensure and Certification, Health Care Authority, Charleston, WV). Personal communication. May. 10. 2005:1.
117 Hochman L. (Division of Health Care Financing, Madison, WI). Personal communication. May. 6. 2005:1.
118 McLean J. (Wyoming Department of Health, Cheyenne, WY). Personal communication. Apr. 19. 2005:1.
119 6 CCR 1011-1, Chapter XX. State Board of Health Ambulatory Surgical Center. Last amended November 16, 1994, effective January 30, 1995. Denver (CO). Colorado Department of Public Health and Environment. 1995:18.
120 Rarey GF. (Department of Public Health and Environment, Denver, CO). Personal communication. May. 12. 2005:1.
121 Peterson ME. (Department of Health and Social Services, Wilmington, DE). Personal communication. May. 4. 2005:2.
122 IOWA ADMIN. CODE r.641-203.2(135) (2005). Public Health Department [641]. Chapter 203: Standards for certificate of need review.
123 MASS. REGS. CODE tit. 105, § 130.900 (2005). Title 105: Department of Public Health. Chapter 130.000: Hospital licensure.
124 Horvath L. (Health Policy, Regulation and Professions Administration. Michigan Department of Community Health. Lansing, MI). Personal communication. May. 2. 2005:1.
125 Mississippi State Department of Health. Certificate of need criteria and standards for cardiac catheterization services and open-heart surgery services. Jackson (MS). Mississippi State Department of Health. 11.
126 N.H. CODE ADMIN. R. ANN. He-Hea 1100. Chapter He-Hea 1100 Cardiac Services.
127 N.J. ADMIN. CODE § 8:33E-1.3. Title 8. Department of Health and Senior Services Chapter 33E. Certificate of Need: cardiac diagnostic facilities and cardiac surgery centers. Subchapter 1. Cardiac diagnostic facilities.
128 Waselauskas PM. (State Department of Health, Albany, NY). Personal communication. Apr. 14. 2005:1.
129 N.Y. COMP. CODES R & REGS. tit.10 § 709.14 (2005). Title 10: Department of Health. Part 709: Determination of public need for medical facility construction. Section 14: Cardiac care services.
130 N.C. ADMIN CODE tit. 10A, r. 14C.1602 (2005). Title 10A: Department of Health and Human Services. Subchapter 14C: Certificate of need regulations. Section 1602: Criteria and standards for cardiac catheterization equipment and cardiac angioplasty equipment.
131 OHIO ADMIN. CODE § 3701-84-30 (Anderson 2004). Chapter 3701-84: Standards for Providers of health care services. Section 30: Adult cardiac catheterization service standards.
132 PA. CODE § 138.14 (2005). Title 28. Health and safety. Chapter 138. Cardiac catheterization services, general provisions. Section 14. Programs and services.
133 Certificate of need guidelines. [internet]. Montpelier (VT). Department of Banking, Insurance, Securities and Health Care Administration. cited 2005 Apr 27. 1999:27. Available: http://www.bishca.state.vt.us/HcaDiv/CON_/CON-Application_packet/CON_guidelines.htm.