# APPENDICES: SUPPORTING DOCUMENTATION AND EVIDENCE TABLES

Appendix A Literature Searches

Appendix B Excluded Studies

Appendix C Evidence Tables for Key Question 1

Appendix D Evidence Tables for Key Question 3

Appendix E Evidence Tables for Key Question 4

Appendix F Regulations and Standards (Key Question 5)