# References

1 Young T, Palta M, Dempsey J, Skatrud J, Weber S, Badr S. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328:1230-1235. [pmid: 8464434].
2 Ferber R, Millman R, Coppola M, et al. Portable recording in the assessment of obstructive sleep apnea. ASDA standards of practice. Sleep. 1994;17:378-392. [pmid: 7973323].
3 Flemons WW, Littner MR, Rowley JA, et al. Home diagnosis of sleep apnea: a systematic review of the literature. An evidence review cosponsored by the American Academy of Sleep Medicine, the American College of Chest Physicians, and the American Thoracic Society. Chest. 2003;124:1543-1579. [pmid: 14555592].
4 Flemons WW, Littner MR. Measuring agreement between diagnostic devices. Chest. 2003;124:1535-1542. [pmid: 14555591].
5 Chesson AL Jr, Berry RB, Pack A. Practice parameters for the use of portable monitoring devices in the investigation of suspected obstructive sleep apnea in adults. Sleep. 2003;26:907-913. [pmid: 14655928].
6 ATS/ACCP/AASM Taskforce Steering Committee. Executive summary on the systematic review and practice parameters for portable monitoring in the investigation of suspected sleep apnea in adults. Am J Respir Crit Care Med. 2004;169:11603.
7 Institute for Clinical Systems Improvement (ICSI). Diagnosis and Treatment of Obstructive Sleep Apnea. Bloomington (MN). Institute for Clinical Systems Improvement (ICSI). 2004.
8 Sackett DL, Strauss SE, Richardson WS, Rosenberg W, Haynes RB. Diagnosis and Screening in Evidence Based Medicine: How to Practice and Teach EBM. Edinburgh. Churchill Livingstone. 2000:67-93.
9 Marrone O, Salvaggio A, Insalaco G, Bonsignore MR, Bonsignore G. Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Arch Chest Dis. 2001;56:486-490. [pmid: 11980277].
10 Calleja JM, Esnaola S, Rubio R, Duran J. Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. Eur Respir J. 2002;20:1505-1510. [pmid: 12503711].
11 Golpe R, Jimenez A, Carpizo R. Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest. 2002;122:1156-1161. [pmid: 12377836].
12 Shochat T, Hadas N, Kerkhofs M, et al. The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. Eur Respir J. 2002;19:121-126. [pmid: 11843310].
13 Ayas NT, Pittman S, MacDonald M, White DP. Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Med. 2003;4:435-442. [pmid: 14592285].
14 Bar A, Pillar G, Dvir I, Sheffy J, Schnall RP, Lavie P. Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies. Chest. 2003;123:695-703. [pmid: 12628865].
15 Dingli K, Coleman EL, Vennelle M, et al. Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. Eur Respir J. 2003;21:253-259. [pmid: 12608438].
16 Reichert JA, Bloch DA, Cundiff E, Votteri BA. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Med. 2003;4:213-218. [pmid: 14592324].
17 Pillar G, Bar A, Betito M, et al. An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Med. 2003;4:207-212. [pmid: 14592323].
18 Zamarron C, Gude F, Barcala J, Rodriguez JR, Romero PV. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest. 2003;123:1567-1576. [pmid: 12740275].
19 Liesching TN, Carlisle C, Marte A, Bonitati A, Millman RP. Evaluation of the accuracy of SNAP technology sleep sonography in detecting obstructive sleep apnea in adults compared to standard polysomnography. Chest. 2004;125:886-891. [pmid: 15006946].
20 Gurubhagavatula I, Maislin G, Nkwuo JE, Pack AI. Occupational screening for obstructive sleep apnea in commercial drivers. 2004;170(4):371-376.
21 Pillar G, Bar A, Shlitner A, Schnall R, Shefy J, Lavie P. Autonomic arousal index: an automated detection based on peripheral arterial tonometry. Sleep. 2002;25:543-549. [pmid: 12150321].
22 Whitney CW, Enright PL, Newman AB, Bonekat W, Foley D, Quan SF. Correlates of daytime sleepiness in 4578 elderly persons: the Cardiovascular Health Study. Sleep. 1998;21:27-36. [pmid: 9485530].
23 Ohayon MM, Roth T. Prevalence of restless legs syndrome and periodic limb movement disorder in the general population. J Psychosom Res. 2002;53:547-554. [pmid: 12127170].
24 Young T, Shahar E, Nieto FJ, et al. Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med. 2002;162:893-900. [pmid: 11966340].
25 Kapur VK, Rapoport DM, Sanders MH, et al. Rates of sensor loss in unattended homy polysomnography: The influence of sage, gender, obesity, and sleep-disordered breathing. Sleep. 2000;23:1-7.