# Results

The updated literature search described in Chapter 2 initially produced 172 titles and abstracts that were reviewed against the inclusion and exclusion criteria. We obtained 15 articles for full review and ultimately retained 12 articles as relevant to the key questions detailed in Chapter 1. They date from 2001 through 2004.^9–20^

We excluded studies for a variety of reasons. These typically included the fact that polysomnography (PSG) studies were not performed on all patients, that the portable device was only an electroencephalogram (EEG), and that the study assessed a telemedicine approach that did not compare a portable device to the PSG.

The remainder of this chapter describes the studies in terms of type of device, setting, populations, and similar design characteristics and summarizes some qualitative findings on this evidence base. We then present specific information drawn from five articles in which the portable device was tested in a home setting. Detailed information on all 12 studies (Table 3) can be found in the evidence tables in Appendix C.

As noted in Chapter 1, the chief issues for this review concern the diagnostic test properties of unattended, portable sleep testing devices compared with those of facility-based PSG in diagnosing obstructive sleep apnea (OSA). Two subsidiary questions, predicated on similar effectiveness, concerned the parameters of sleep and cardiorespiratory function that needed to be measured and the various factors, such as patient education or technician support, that would be needed to ensure home testing is done correctly in the home.

## General Overview

### Types of Devices

As described in Chapter 1, diagnostic testing for OSA can be done through techniques and devices classified into four types. The most comprehensive is designated Type 1: attended, in-facility PSG. Portable devices for home use are then classified (in descending order of complexity of elements measured, with particular emphasis on respiratory effort) as Type 2, 3, or 4.

Of the 12 studies reviewed, four dealt with Type 3 portable testing devices;9,10,15,16 eight concerned Type 4 devices.11–14,17–20 Most dealt with devices with similar technology that had been reviewed previously.

Only one significantly different technology that was not in the previous review ─ peripheral arterial tonometry (PAT, using the Watch_PAT 100 device manufactured by Itamar Medical Ltd., located in Haifa, Israel and Boston, Massachusetts) ─ was reported in studies that met our inclusion criteria.13,14,17 This is a Type 4 device because it does not measure respiratory effort or airflow.

### Patient Populations

Most patient populations were recruited as consecutive subjects, typically having been referred to sleep clinics or laboratories for suspected OSA. Two studies used healthy volunteers as well,14,17 and one referred to a group at “low risk” of apnea.20

More subjects were male than female; most were middle-aged (mean ages in their 40s and 50s). Studies rarely reported ethnicity or race. Of the studies reporting the data, the average body mass index measures were in the range of overweight or obese; only three studies reported comorbidities (cardiovascular disease or chronic obstructive pulmonary disease; one reported smoking behaviors).

### Location of Studies

Ten studies were done outside the United States (some in multiple countries): Spain, three studies; Israel, three studies; and Scotland, Germany, Belgium, and Italy, all one study each. U.S. sites were in California, Massachusetts, and Rhode Island.

Of the included 12 studies, five investigated the use of portable devices in the patients’ homes;11,14–16,19 of these, three investigations of the portable device were also done in laboratory settings. All other studies of the portable devices were conducted solely in sleep laboratories.

### Implementation of Testing Studies

Of the 10 studies in which some form of testing of the portable device occurred in a laboratory setting, the investigators did not report whether the portable device was attended or unattended for six studies; one was reported as unattended10 and one was reported as attended but the technician was not permitted to view signals from the portable device.9 None of the five home-based studies or substudies was attended. Thus, this body of new evidence does reflect a set of investigations (unattended portable devices) relevant to the main key question.

All studies compared portable device results against those of PSG; that is, all included studies had to have had PSG tests performed. Ten studies did these two tests simultaneously (“concomitantly,” “synchronously”) in the sleep laboratories; two had PSG testing only at times with variable intervals from that of the portable device test.

Of the five studies with home-based testing, the temporal relationship of it to the PSG test varied considerably. For the two with only home-based testing, the relationship in one was between 2 and 40 days after the PSG15 and in the other up to 30 days before a PSG.11

The mode of hook-ups was not reported for six studies; for an additional two studies, hook-ups could be assumed from information in the articles to have been by technicians. For the five home studies, hook-ups were only by patients in all except one study in which half of the hook-ups were by technicians and half by the patients.11

Education of patients for using the portable devices at home varied considerably. Two home studies did not describe these procedures; in the others, patients received a 20-minute educational intervention by a trained technician and written instructions,15 a 15- to 20-minute training period and written instructions,11 and no direct training or instructions but rather a “Quick Guide,” instructional video, and 24-hour help-line telephone number.16

### Scoring and Interpreting Portable Monitor Results

Portable device results could be scored automatically or manually (or both). Two studies did not describe scoring.19,20 Scoring was described only as “automated” for five studies (four in-laboratory studies12,13,18,21 and one in-home study16). In addition, three studies noted automated scoring with various manual adjuncts or corrections;9–11 one specified automated scoring with a proprietary algorithm,14 and one used manual and automated scoring of apnea and hypopnea and reported that automated scoring did not correlate well with the manual scoring of the PSG results.15

Virtually no studies described the qualifications of the individuals who interpreted the results of portable monitors. In one study, an “experienced neurophysiologist” interpreted results;10 in another, a physician was the investigator responsible for portable device interpretation.11

### Sponsorship of Studies

Several studies were done by the same teams of investigators. For six studies, the sources of funding were not given (although in some cases the apparent source of funding was the device manufacturer). In several cases, some or all of the investigators were employees of or consultants or scientific advisers to the company manufacturing the device.12–14,17

### Quality of Studies and Strength of Evidence

Of these 12 studies, seven provided “Level I” evidence: random or consecutive assignment to the study as a whole; outcomes evaluators blinded to the results of the PSG or the portable device results; and reference standard (PSG) done on both populations. Two studies were “Level II,” which blinded outcomes evaluations and did reference standards but did not assign patients randomly or consecutively.10,19 Evidence Level III (outcomes evaluators blinded and patients assigned randomly or consecutively, but no reference standard performed on all patients) was not a relevant category for this review because we required a PSG on all subjects as an inclusion criterion. Three studies (all in-laboratory) were Level IV evidence (no blinding12,13,17).

Using these levels of evidence categories and scores on the eight quality indicators (present or absent), we graded the quality of studies as good, fair, or poor (see Table 2 in Chapter 2). When data were not reported, we assumed the quality indicators were not met (i.e., were absent). Of these 12 studies, one was considered good;15 four were considered fair;10,11,14,18 and seven were considered poor.9,12,13,16,17,19,20

Generally, the overall quality grades for this set of studies could be characterized as at best only fair; we did not drop studies from inclusion in the report itself because of a quality grade of poor. Most studies were small to medium sized (except for the one large study of commercial drivers).

## Important Findings from Reviewed Studies

For this update, we focused on the five studies with in-home results (regardless of whether those studies also included in-laboratory results). However, four studies with in-laboratory results comparing portable devices with PSG results were rated good or fair, and we briefly comment on those just below. Authors variably reported sensitivity and specificity statistics and/or likelihood ratios (LRs); the latter provide a convenient way to estimate the change in the probabilities that a disease is present after test results are known relative to the pretest probabilities.

### Portable Devices Studied in the Laboratory

Three teams compared Type 3 devices against PSG in the laboratory setting (Evidence Tables 1, 2, and 4).10,15,16 In one study, the investigators used simultaneous unattended studies and did not report on hook-up, but did comment that the outcomes interpreter was an experienced neurophysiologist.10 For comparisons of PSG with manual scoring of the portable device at AHI ≥ 15 (15.8 for the portable device), sensitivity was 90.6 percent and specificity 80.8 percent; values at other AHI cutoffs were generally similar. The authors noted that manual scoring discriminated better than did automated scoring at all AHI cutoffs and that differences were greater at higher AHI cutoff points (suggesting that the portable device might underestimate severe OSA cases). In the other laboratory-based study (fair quality), the timing was simultaneous, hook-ups were done by trained technicians (and presumably the test was attended).15 Bland-Altman plots indicated that the agreement between manual analysis of portable and PSG recordings had a kappa statistic of 0.62 (P < 0.001) and agreement on nasal pressure changes a kappa statistic of 0.57 (P < 0.01). The authors reported that agreement between the PSG and automated portable analysis was poor.

In the Reichert study, the laboratory comparison was done simultaneously with the PSG. The hook-up for the portable device was not described, but it was likely done by trained technicians. No discussion was given of whether the technicians intervened to fix any problems encountered with the portable monitoring equipment during this attended study.16 Using a threshold of AHI of 15 on PSG to define the presence of OSA, the sensitivity and specificity for portable monitoring was good at 95%±5% and 91%±6% respectively. The overall agreement (0.932) had a kappa coefficient for agreement beyond chance of 0.864, which is very good.

Two studies judged fair examined the performance of Type 4 devices in laboratories (Evidence Tables 6 and 12).14,18 One study mainly studied portable devices vis-à-vis PSG in a laboratory setting (and did a small subsample in-home study reported below).14 The in-laboratory tests were simultaneous, but the investigators did not report how the hook-ups were done in the laboratory, whether the in-laboratory tests were attended, or the qualifications of the individuals doing the test interpretations. Portable results were scored with an automated (proprietary) algorithm; PSG results were done with manual scoring. The authors reported a correlation of 0.88 (P < 0.0001) for AHI/RDI results between the portable and the PSG results. Another research team did simultaneous testing of the portable device and PSG and implied that patient hook-up in both cases was done by a technician; they did not specify if the tests were attended.18 Using a measure of oxygen saturation and heart rate, they reported a sensitivity of 94 percent and specificity of 82 percent, for LR+ of 5.35 and LR- of 0.07. The authors concluded that if the portable test were negative, it was unlikely that the patient would receive a diagnosis of OSA.

### Portable Devices Studied in the Home

As noted, our focus was on results from in-home uses of these portable devices, not in-laboratory applications. Table 4 summarizes information for these five articles; two dealt with Type 3 devices and three with Type 4 devices. We describe all five studies below and in Evidence Tables 2, 4, 6, 7, and 9.

Reichert et al. enrolled 51 patients using the NovaSomQSG (Type 3) device estimating oro-nasal airflow by sound, oxygen saturation, heart rate, respiratory effort and snoring (quality grade, poor).16 Of these, 45 completed the study; three did not use the portable system at home and three had a portable device with a faulty memory chip. Thus, the level of missing data (i.e., patients for whom data could not be collected or analyzed of all patients entered into the study) was 13 percent. The home studies were done within 7 days before or after an in-facility PSG (half before, half after). The proportion of males in the analysis group was not reported but 38 (75 percent) of the total group of 51 in the initial sample were men. The prevalence of OSA by PSG, defined as an apnea/hypopnea index (AHI) level of >15, was 47 percent (20 of 44 patients); however, the authors reported that 40 of the patients had “split-night” studies in the laboratory, suggesting that a larger percentage had some degree of OSA. AHI scores for the home study were averaged across 3 nights. Using this average would tend to decrease the effect of variability of results of the home device and thus tend to increase the observed agreement with PSG results.

When the AHI defining a positive test was set at 15 or higher, the sensitivity for the home tests was 91 percent (± 6 percent) and the specificity was 83 percent (± 8 percent); these values led to a positive predictive value of 83 percent and a negative predictive value of 91 percent. The sensitivity/specificity values give an LR+ of 5.35 and an LR- of 0.11, indicating a modest increase in probability of OSA if the test is positive and a modest decrease in the probability if it is negative. A Bland-Altman plot showed wide confidence limits for agreement on AHI with 2 SD approximately equal to 60.

Dingli et al. enrolled 61 patients with Type 3 equipment (Embletta) that measured flow by nasal pressure detector, thoraco-abdominal movement, pulse oximetry, and body position (quality grade, good).15 Overall, 18 percent of these home studies had inadequate data, leaving 50 patients in the analysis. The rate of data loss was reported to improve because of a “learning effect” among the last two-thirds of patients studied, but the rate of loss was still 12 percent even in these patients. The overall prevalence of sleep apnea defined by a PSG AHI greater than 15 was 76 percent.

Using two different thresholds for the number of apneas plus hypopneas per hour (A+H/hr) in the home study to classify patients as positive or negative for OSA (home A+H/hr > 20 = positive; home A+H/hr < 10 = negative), no false-positive and no false-negative cases occurred. However, 36 percent of cases had home study results with values for A+H/hr in the “indeterminate” range; thus, the investigators could not classify these patients as having or not having OSA. The authors reported that agreement between the Embletta automated scoring and PSG results yielded a kappa coefficient of 0.10 (poor agreement) and agreement between Embletta manual scoring and PSG a kappa of 0.54. The A+H/hr measured on the portable study agreed more closely with that from the PSG when thoraco-abdominal movement was used in conjunction with flow by nasal pressure to determine hypopneas. The authors stated that use of nasal pressure as the sole indicator of hypopneas would result in unscorable traces in approximately 8 percent of studies and recommended use of both measures to define hypopneas. In summary, in this study, although no misclassification occurred using different thresholds for a positive or a negative home study, a large proportion of patients would require additional testing.

Golpe et al. enrolled 55 patients in their home study using a Type 4 device (Apnoescreen) that recorded body position, wrist actimetry, pulse oximetry, pulse rate, and oronasal airflow by thermistry (quality grade, fair).11 Overall, 20 percent of the patients in the home studies produced no interpretable data – 7 percent of 28 patients whose equipment was set up by a technician and 33 percent of 27 patients who did their own hook-ups.

For detection of OSA defined as an AHI of 10 or greater by PSG, the best sensitivity and specificity estimates from the “knee” of the receiver operating characteristics (ROC) curve were approximately 90 percent and 80 percent, respectively. These values yield a LR+ of 4.5 (considered a modest change in likelihood of OSA from the pretest probability if the test is positive) and a LR- of 0.125 (considered a modest decrease in the likelihood of OSA if the test is negative).

These authors also reported the agreement between therapeutic decisions derived from the home studies and PSGs. The clinical decision on whether to treat the patient with CPAP based on the home study result agreed with that based on the PSG in 34 of 44 cases (77 percent). In six of the 10 cases of nonagreement, diagnostic classifications clearly differed: one home study false-negative result and three false-positive results. In three cases, although both types of study classified the patients as having OSA, the home study overestimated the severity inasmuch as the clinician judged that only conservative treatment was indicated. In the remaining case, the home study was inconclusive but PSG results showed that CPAP was indicated.

Liesching et al. retrospectively studied at total of 36 patients with a Type 4 device (SNAP) that monitored oronasal sound to estimate airflow (quality grade, poor).19 Four patients had only split-night PSGs (with CPAP initiated during the study), so the investigators could not compare their results with SNAP home study results. SNAP results were also inadequate to estimate AHI in one additional patient, leaving 31 patients in the analysis (for a 3 percent rate of missing data).

Patients were classified by PSG results as normal (AHI < 5), mild OSA (AHI 5 – 15), moderate OSA (AHI 15 – 30), or severe OSA (AHI > 30). Of the eight patients who were normal by PSG, SNAP classified all as having OSA (six mild, one moderate, one severe); these figures yielded a specificity of 0 percent. Considering only the normal patients whom SNAP classified as either moderate or severe OSA as false-positives, specificity was 75 percent. SNAP results classified 21 of the 23 OSA cases (by PSG) as positive (91 percent sensitivity); one false-negative case by SNAP was classified as severe by PSG and the other as moderate.

The LR+ is 0.91 if all false-positive cases are included in specificity; it is 3.64 if only those normal patients misclassified as moderate or severe OSA by SNAP are considered. The LR- value is 0.12 in this latter circumstance. Thus, the test provides little change in the estimated probability of OSA if it is positive and a modest reduction in the probability of OSA if it is negative.

Bar et al. used a new Type 4 device measuring peripheral arterial tonometry, pulse oximetry, and actigraphy (Watch PAT 100) in home studies in 14 patients (quality grade, fair).14 This study had both a simultaneous in-laboratory comparison with PSG (see above) and a “subset” of 14 patients studied in the home; on two additional nights of the latter, three studies did not produce usable data, for a data loss of 11 percent.

Sensitivity and specificity were not explicitly reported for the home study. However, from the RDI values from home and PSG testing given for each subject (Figure 5, p. 699) and defining the presence of OSA by a PSG RDI of 20 or higher, we calculated that nine patients had OSA (64 percent prevalence). PAT home study detected seven of these nine cases (sensitivity, 78 percent) and had two false-positive results (specificity, 60 percent). One false-positive result by PAT had a PSG RDI of approximately 19, so if this case is considered correctly classified as positive by PAT, then sensitivity rises to 80 percent and specificity to 75 percent. Even with these estimated values of sensitivity and specificity, LR+ is 3.2 and LR- is 0.27, both indicating little effect of test results on the estimated likelihood of OSA.

Table 3 Twelve Included Studies with Type of Device, Site of Test, and Quality Grade

Study | Type and Name of Device | Site of Tests | Quality Grade (Evidence Table^*^)
Calleja et al., 2002^10^ | Type 3 MERLIN | Sleep laboratory only | Fair (ET1)
Marrone et al., 2001^9^ | Type 3 POLYMESAM | Sleep laboratory only | Poor (ET3)
Dingli et al., 2003^15^ | Type 3 Embletta | Home and sleep laboratory | Good (both settings) (ET2)
Reichert et al., 2003^16^ | Type 3 NovaSom QSG | Home and sleep laboratory | Fair (lab study) Poor (home study) (ET4)
Ayas et al., 2003^13^ | Type 4 Watch PAT100 | Sleep laboratory only | Poor (ET5)
Pillar et al., 2003^17^ | Type 4 Watch PAT100 | Sleep laboratory only | Poor (ET 10)
Shochat et al., 2002^12^ | Type 4 SleepStrip™ | Sleep laboratory only | Poor (ET11)
Zamarron et al., 2003^18^ | Type 4 Criticare 504 oximeter | Sleep laboratory only | Fair (ET12)
Gurubhagavatula et al., 2004^20^ | Type 4 Not reported | Sleep laboratory only | Poor (ET8)
Bar et al., 2003^14^ | Type 4 WatchPAT 100 | Home (substudy) and sleep laboratory | Fair (both settings) (ET6)
Golpe et al., 2002^11^ | Type 4 Apnoescreen-I | Home only | Fair (ET7)
Liesching et al., 2004^19^ | Type 4 SNAP technology | Home only | Poor (ET9)

* Evidence tables are found in Appendix C.

Table 4 Summary of Studies of Portable Monitoring Devices Conducted in the Home

Study and Country | Device Tested (Type) | Patient Characteristics | Timing of Home Testing | Number of Patients Enrolled / Completed (Percentage with Missing Data) | Sensitivity and Specificity; kappa^*^ | Other Comments; Quality Grade^†^
Reichert et al., 2003^16^ USA | NovaSom QSG (Type 3) | OSA suspected Elderly: Age range 30–83 years | Half done 7 days before and 7 days after PSG | 51/45 (13%) | RDI ≥ 15: Sens: 91% Spec: 83% k: NR | PPV: 83% NPV: 91% Quality: II-D (poor)
Dingli et al., 2003^15^ Scotland | Embletta (Type 3) | OSA suspected Elderly: Mean age 46 ± 10 years | On 2 separate nights in random order, in 2 to 4 days | 61/50 (18%) | NR k: 0.54 | Thresholds for OSA set at 20 but compared portable at this threshold and used 15 for the PSG Quality: I-A (good)
Lieshing et al., 2004^19^ USA | SNAP (Type 4) | OSA suspected Elderly: Mean age 50.3, range 29 to 77 years | Mean followup of 5 months (range of 2 to 10 months) | 36/31 (16%) | NR Estimated from the article for patients with AHQ ≥5: Sens: 91% Spec: 0% k: 0.23 | Accurately assessed severity: 12 of 31 patients (39%); Accurately predicted AHI: 17 of 31 patients (55%) within 10 events per hour Quality: II-D (poor)
Golpe et al., 2002^11^ Spain | Apnoescreen-I (Type 4) | OSA suspected Elderly: Mean age 52.7 ± 13.3 years | Portable done first, PSG done within 30 days | 55/44 (20%) | NR: Estimated from ROC curve for AHI ≥10: Sens: 90% Spec: 80% k: 0.734 | Half of patients were hooked up by technicians, half by patients themselves Quality: I-C (fair)
Bar et al., 2003^14^ Israel | Watch PAT100 (Type 4) | OSA suspected Elderly: Mean age 41.4 ± 15.2 years | Substudy done on two additional nights | 14/3 (21%) | NR; Estimated from the article RDI ≥ 20: Sens: 78% Spec: 60% k: NR | Did not report home study results versus inlab PSG results; Correlation of in-lab portable results with PSG: r = 0.88 (P < 0.0001) Quality: II-C (fair)

AHI: apnea/hypopnea index; NR: Not reported; OSA: obstructive sleep apnea; PSG, polysomnography; PPV, positive predictive value; NPV, negative predictive value; RDI, respiratory disturbance index

* kappa (k): level of agreement between polysomnography categorization and categorization by portable device tested.

** Percentage of missing data calculated as number of patients not analyzed because of missing data for any reason as a percentage of the total number enrolled.

† Quality grade: see Chapter 2 and Table 2 for explanation