# Methods

## Literature Search Strategy

We updated the literature search used for the previous systematic review that we had completed in 2002, using the same inclusion and exclusion criteria. Both the Agency for Healthcare Research and Quality (AHRQ) and the Centers for Medicare and Medicaid Services (CMS) reviewed and approved these criteria (Table 1).

Table 1 Inclusion and Exclusion Criteria

Inclusion Criteria
Patient populations | Human, both sexes, ages 18 and over, with ANY diagnosis of obstructive sleep apnea (OSA)
Types of OSA diagnostic device | Portable device used for diagnosis AND polysomnography or other acceptable test used for diagnosis of OSA
Sample size | After completion of study, each analysis group is greater than or equal to 10 subjects
Language | Study published in English
Exclusion Criteria
Patient populations | Children (birth through 17 years)
Study types | Reviews, meta-analyses, case reports, abstracts letters, editorials
Language | Other than English

Our search concentrated on articles published since January 1, 2002, a date that coincides with the end of the coverage period for the most recent evidence review.

The basic Medical Subject Headings (MeSH) used in our updated search were polysomnography (PSG), oximetry, physiologic monitoring, and sleep apnea (with limits, as noted in Table 1, of human, adults, and English language). We also included the following terms to help us refine our search: airway resistance, upper airway resistance syndrome, respiratory disturbance index, autoset, snoring, and respiratory events-related arousals. Finally, to understand the scope of the impact of screening on the societal burden of sleep apnea, we added several other search terms: reproducibility of results, predictive value of tests, and sensitivity and specificity.

Our search yielded 172 items with titles and abstracts. Of these, we determined that 15 were eligible for full retrieval and review. We were able to obtain 13 of these articles, but after review, excluded three. We also conducted a handsearch and identified two additional studies, for a total of 12 studies for inclusion in the evidence tables. Some articles identified through handsearching did not meet the criteria for inclusion in the evidence tables, but they did contain information relevant to the key questions and will be referenced in the discussion chapter.

A search of the International Network of Agencies for Health Technologies Assessment (INAHTA) database for Diagnostic Procedures and Screening yielded no relevant reports to review. The National Guidelines Clearinghouse has two guidelines: “Practice parameters for the use of portable monitoring devices in the investigation of suspected sleep apnea in adults”5 by the three professional societies that published manuscripts on our 2002 review, discussed in Chapter 1; and “Diagnosis and treatment of obstructive sleep apnea” by the Institute for Clinical Systems Improvement, also published in 2003.^7^ We reviewed both these documents for potential studies to include in our review and used them as background material for this review. A search of the Cochrane Collaboration Database turned up a number of hits, but further investigation indicated that the studies or reviews so identified were either not relevant to this review or outdated.

## Data Abstraction

We used a data abstraction template from the earlier review to retrieve and enter the relevant information from the articles that presented new evidence (Appendix B). The form includes a general description of study design and outcomes for each arm (device or control/comparison group) studies, including sample size; patient characteristics, types, frequency, and duration of monitoring; outcomes measures; and the statistical significance of differences.

We created evidence tables organized by the level of device (see Chapter 1). The first part of the evidence table describes the diagnostic device and how it is applied/used and the nature of the target population (demographic characteristics, presence of conditions related to sleep apnea or symptoms of sleep apnea). The second part describes the research design and conduct; the third part describes the study outcomes. To ensure consistency, we developed standardized abbreviations and conventions for describing particular pieces of information. The evidence tables can be found in Appendix C.

The evidence tables are formatted to capture detailed, relevant characteristics of each study. They are also flexible enough to accommodate study designs ranging from randomized controlled trials (RCTs) to quasi-experimental and observational studies.

## Quality Ratings

Rating the quality of individual studies is a critical element of any systematic review. For this step, we applied the same quality rating scheme as we used in the 2002 review for grading by the AASM/ACCP/ATS Evidence Review Committee,3 which was based on levels of evidence and quality indicator scores.

The levels of evidence were followed the approach published by Sackett et al.8 and the four levels were defined as follows:

I. Blinded comparison, consecutive patients, reference standard (in this case PSG) performed on all patients;
II. Blinded comparison, nonconsecutive patients, reference standard performed on all patients;
III. Blinded comparison, consecutive patients, reference standard not performed on all patients; and
IV. Reference standard not applied blindly or independently.

For this updated review, we included no Level III studies because of the inclusion criterion that specified that the portable device had to be compared to the PSG, the best-known reference standard at this time. We thus reviewed each study for inclusion of the following three items to determine the level of evidence:

1. Subjects selected consecutively or randomly
2. Reference standard done on all subjects
3. Both tests scored blindly.

If the study did not report on any of the items that make up the assigned level of evidence, we assigned a value of “no.”

For the quality indicators score, we used the original eight indicators developed during the 2002 review and applied them to each study in this review:

- Prospective study;
- Portable device tested outside the sleep laboratory;
- Random order of allocation of subjects to the PSG or portable test first;
- Low data loss, specifically ≤ 10 percent of flow/SaO_2_/EEG, as applicable;
- High percentage of completions (≥90% of those entered);
- PSG methodology fully described;
- Portable methodology fully described;
- Portable scoring fully described.

As with the levels of evidence, if the study did not report on an indicator, then we assigned a “no” value; for the third item above (random order), we scored “not applicable” when the portable and the PSG tests were done simultaneously. Using the results of the number of quality indicators that were met for each study, we calculated an overall quality indicator score based on the categories defined below:

Quality rating:

A. Zero or only one quality indicator NOT met;
B. Two quality indicators NOT met;
C. Three quality indicators NOT met; or
D. Four or more quality indicators NOT met.

For ease of interpretation, we developed a summary quality grade for each article. We used the above methodology and then arbitrarily assigned a grade for each combination of level of evidence and quality score. Table 2 below shows the specific mapping of each category for the levels of evidence and quality indicator scores to each individual quality grade.

Table 2 Quality Grades Based on Levels of Evidence and Scores on Quality Indicators

Grades | Levels of Evidence and Quality Indicator Scores
| Level I | Level II | Level III | Level IV
Good | A, B | | NA
Fair | C | A, B, C | NA | A, B
Poor | D | D | NA | C, D

NOTE: Scores on eight quality indicators: A, 0 –1 missed; B, 2 missed; C, 3 missed; D, 4 or more missed. Level III evidence was not applicable for this updated review. No Level II or IV studies could be considered good evidence (see text for discussion).