# Introduction

## Background

Obstructive sleep apnea (OSA, sometimes characterized as obstructive sleep apnea syndrome) is now recognized to be a significant and serious public health problem. Researchers have estimated that approximately 2 percent to 4 percent of middle-aged women and men, respectively, have this condition; the majority (approximately 80 percent to 90 percent in one study1) remain undiagnosed. Undiagnosed and thus untreated, OSA is associated with significant morbidity and mortality, including excessive daytime somnolence, increased risk of automobile crashes, hypertension, cardiovascular disease, stroke, and metabolic abnormalities.

Effective treatment modalities are available, primarily nocturnal continuous positive airway pressure (CPAP) and in some instances surgical procedures or dental appliances. These treatments, however, are expensive and have potential side effects, so they should not be applied without an accurately established diagnosis of OSA.

Medical history and physical examination can provide an estimate of the likelihood of OSA, but they are not sufficient to establish the diagnosis or its severity. Therefore, patients suspected of having this condition must be evaluated with a diagnostic test that can provide a significant increase (“rule in”) or decrease (“rule out”) in the likelihood of the condition so that proper management can be implemented.

Using the reference standard polysomnography (PSG), which is a facility-based diagnostic intervention, is expensive. Because of limited facilities, waiting time for studies after the diagnosis is suspected on clinical grounds has been excessive in many areas of the country. Thus, various groups have attempted to develop portable technologies that can accurately classify patients as either having a very low likelihood of OSA and thus not need a PSG or having a very high likelihood of OSA and for whom management with a CPAP titration or other procedure should be initiated. The goal is to reduce the need for expensive laboratory testing while increasing the rapidity of diagnosis and initiation of appropriate management.

The first step in determining whether a portable monitoring device can achieve this goal is to determine its accuracy in characterizing the presence and severity of sleep-disordered breathing events relative to the reference standard PSG in a controlled study. This is the focus of most of the research papers published on portable monitors for OSA, and it was the main factor considered in the last systematic evidence review (described below). However, other considerations are also important in the overall assessment of whether the current technologies will be cost effective and provide adequate accuracy of diagnosis if applied to a large population of patients in unattended settings. These issues are examined further in the Discussion chapter of this report.

## Evaluating the Role of Home Testing of Obstructive Sleep Apnea

As noted, various portable devices have been developed over the past decade that are meant to be used as screening tools or replacements for the labor-intensive, complex, expensive, laboratory- or facility-based PSG for the evaluation of patients suspected of having OSA.

The American Sleep Disorders Association classified monitors used in diagnostic testing for sleep apnea into four types.2 Attended PSG, Type 1, is the gold standard, and the portable monitors fall into three types (2, 3, and 4) with fewer physiologic signals monitored in each subsequent type. The levels are briefly defined below to clarify the differences between them:

- Type 1: Measures, at a minimum, eight channels ─ electroencephalogram (EEG), electro-oculogram (EOG), electrocardiogram (ECG), chin electromyogram (EMG), airflow, respiratory “effort,” oxygen saturation (SaO_2_), and body position; it is attended in a laboratory setting.
- Type 2: Monitors a minimum of seven channels including EEG, EOG, chin EMG, ECG or heart rate, airflow, respiratory effort, and SaO_2_. This allows for sleep staging and measurement of total sleep time, and this information can be used to determine in the number of sleep-disordered breathing events per hour of sleep (e.g., the apnea/hypopnea index).
- Type 3: Includes a minimum of four channels and must monitor at least two channels of respiratory movement or respiratory movement and airflow to define an event; generally, no EEG signals are monitored.
- Level 4: Includes only one or two channels of physiologic signals and generally uses only one channel (either SaO_2_ or airflow) to define a sleep-disordered breathing event; no EEG signals are monitored.

## The Original 2002 RTI-UNC Systematic Evidence Review

In 2002, RTI International (RTI) and the University of North Carolina at Chapel Hill (UNC) completed a systematic review of published articles on home diagnostic testing for sleep apnea in collaboration with three professional organizations: the American Academy of Sleep Medicine (ASSM), the American College of Chest Physicians (ACCP), and the American Thoracic Society (ATS). The RTI-UNC team conducted the literature search and prepared the evidence tables. Members of the three organizations analyzed the data and prepared three key publications.

The full evidence review was subsequently published in the journal Chest in October 2003.^3^ An article in the same issue of Chest measured agreement between diagnostic devices.4 Finally, new recommended clinical practice guidelines (practice parameters) from these three professional organizations for the use of portable monitoring devices in the investigation of suspected obstructive sleep apnea (SOSA) in adults was published in Sleep.5 An executive summary of the systematic review and practice parameters listed above was published in 2004 in the American Journal of Respiratory and Critical Care Medicine.6

The 2002 review compared all of the portable devices to the Type 1, attended, in-laboratory PSG. Although the accuracy of a single-night PSG in determining the presence or absence of clinically significant OSA does have certain limitations (see Discussion section of this report), to date no better standard has emerged. Therefore, this review also compares portable home monitoring devices to the PSG.

The most widely used measure to define the presence and severity of OSA by PSG is the apnea/hyponea index (AHI). Apneas in this calculation are events with complete cessation of airflow; hypopneas are events with decreases in airflow without complete cessation but with associated decreases in SaO_2_ or EEG arousals (or both) depending on the definition used by the researcher or clinician. The AHI is the number of disordered breathing events per hour of sleep calculated from the total number of apneas and hypopneas. Most studies use a lower cutoff level for the AHI to define the presence of OSA by PSG; increasing levels of AHI indicate increasing severity of OSA.

If portable monitoring does not allow for determination of sleep time, then the AHI cannot be calculated. Instead, researchers calculate the number of disordered breathing events per hour in bed or per hour of monitoring time and report this as the respiratory disturbance index (RDI). The RDI can be compared with the same measure calculated from a PSG.

In our original (2002) evidence report, we included 51 studies. Of these, four studies were of Type 2 devices, 12 of Type 3, and 35 of the Type 4. The joint ATS/ACCP/AASM summary of the evidence review and practice parameters stated that data were not adequate to recommend the clinical use of Type 2 portable monitors in either attended or unattended settings. Neither sensitivity nor specificity data were available; moreover, the number of studies of Type 2 devices was small. Overall, the level of evidence was low. Some Type 3 monitors appeared to be potentially acceptable in the attended laboratory setting, but six limitations were noted:

1. Careful review of raw data is necessary (e.g., manual or a combination of automatic and manual scoring).
2. The devices should be used only in populations that have been studied (e.g., those in a sleep clinic population) and should not be applied as generalized screening or in populations with significant comorbidity such as chronic obstructive pulmonary disease or congestive heart failure.
3. AHI in these devices tends to underestimate the PSG-defined AHI because these devices do not measure sleep time.
4. Symptomatic patients with a nondiagnostic or negative Type 3 study should undergo definitive evaluation to determine the cause of symptoms; if a sleep disorder requiring a sleep study is still a clinical consideration, then a full attended PSG should be used.
5. Patients with a positive Type 3 study need a subsequent PSG if CPAP titration is needed.
6. Type 3 portable monitors are not recommended for split-night studies.6

In essence, these Type 3 devices were not recommended for unattended use in the home. Type 4 devices were not recommended for diagnostic use or to assess the probability that a patient may or may not have OSA.

Overall, portable devices were not recommended either for general screening or for patients with certain comorbid conditions. Manual scoring by “physicians with specific sleep training and familiarity with the devices and their limitations” was recommended rather than use of the automated scoring available for some portable devices.

## Purpose of this Updated Evidence Report

RTI is now assisting the Agency for Healthcare Quality and Research (AHRQ) to develop a summary of the available clinical and scientific evidence on home diagnosis of OSA since the last review in 2002. The Centers for Medicare and Medicaid Services (CMS) commissioned AHRQ to provide a technology assessment in preparation for a Medicare Coverage Advisory Committee (MCAC) meeting on September 28, 2004, at which the MCAC will review the evidence.

CMS has provided one key question for this evidence review, with two subquestions based on the results of the main question:

1. How does the diagnostic test performance of unattended portable multi-channel home sleep testing compare to facility-based polysomnography in the diagnosis of obstructive sleep apnea?
  a. If unattended portable multi-channel home sleep testing is as effective as polysomnography in the diagnosis of obstructive sleep apnea, which parameters of sleep and cardiorespiratory function (i.e., sleep staging, body position, limb movements, respiratory effort, airflow, oxygen saturation, electrocardiogram) are required?
  b. If unattended portable multi-channel home sleep testing is as effective as polysomnography in the diagnosis of obstructive sleep apnea, what conditions (i.e., patient education, technician support) are required so that it is done correctly in the home?

In this updated review we report on 12 studies published since the last full review in 2002 that present data on the use of portable monitoring devices for evaluation of OSA.

Chapter 2 describes our methods for this update. Chapter 3 presents our findings from the updated evidence review and Chapter 4 discusses the implications of our results. Acknowledgments can be found in Appendix A; our data abstraction form is in Appendix B; evidence tables (one per study) appear in Appendix C.