# Evidence Tables

Evidence Table 1 Calleja et al., 2002: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Calleja JM, Esnaola S, Rubio R, Duran J Comparison of a cardiorespiratory device versus polysomnography for a diagnosis of sleep apnea. European Respiratory Journal, 2002^10^ Study Location/Sponsor: Spain/ Department of Health, Basque Government Type: 3 | Device: MERLIN Equipment & Methodology: Cardiorespiratory polygraph Channels: Oronasal flow, chest and abdominal respiratory movement, tracheal sound, cardiac frequency, oxygen saturation, body position, CPAP Flow: Thermister Effort: NR Portable Setting: Sleep lab Mode: Unattended Hook-up: NR Timing: Simultaneous | Site: Sleep clinic Inclusion: Adult patients with clinical suspicion of sleep apnea referred from sleep outpatient clinic to sleep lab Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 86 Excluded: NR Entered: 86 Dropout: NR Data Loss: 7 (8%) Analyzed: 79

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 89% Mean BMI: 30.1 Range: NR SD: ± 4.4 kg/m^2^ Mean Age: 52 Range: NR SD: ± 11.1 years % Non-White: NR Prevalence of OSA by PSG: AHI>10: 81% Ave AHI: 41.8 SD: ± 27.7 Comorbidities: NR | Setting: Sleep Lab Equipment & Methodology: Alice 3 or Ultrasom Channels: EEG (C4-A1, C3-A2), EOG, tracheal sound with microphone, tibial and submental EMGs, ECG (modified V2 lead), respiratory sensors, chest and abdominal effort, oxyhemoglobin saturation by finger pulse oximeter, and body position Flow: Thermisters Effort: Belt sensors – piezo-electric gauge | Scoring: Manual- each 30 s epoch scored for sleep state, breathing, oxygenation and movement Blinding: To results of other method Criteria for Excluding Data: NR Qualifications: Neurophysiologist with broad experience in diagnosis of sleep apnea | Scoring: Automated with manual visual evaluation of printouts Blinding: To results of other method Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: Experienced Neurophysiologist – different from the PSG interpreter

Comparison of Results | Special Statistics
Definitions:; - Apnea: complete cessation of thermister signal of ≥ 10 s; - Hypopnea: discernible reduction of ≥50% of the thermister signal for > 10 s accompanied by a decrease of ≥ 3% oxyhemoglobin saturation and/or an EEG arousal; - AHI: PSG uses Total Sleep Time for a denominator vs per hour of polygraphic recording in the portable; AHI/RDI: Avg PSG: 34.4 (29.2) Portable: 10.4 (18.2) for automated scoring; 30.5 (24.5) for manual scoring [underlined: Manual score comparisons:] For AHI ≥ 5 (6.7 cut off point for portable); - Sensitivity – 97.1 (93–100); - Specificity – 90.9 (74–100); For AHI ≥ 10 (9.8 cut off point for portable); - Sensitivity – 90.6 (83–98); - Specificity – 86.7 (69–100); For AHI ≥ 15 (15.8 cut off point for portable); - Sensitivity – 90.6 (83–98); - Specificity – 80.8 (66–96); For AHI ≥ 20 (21.1 cut off point for portable); - Sensitivity – 91.1 (83–99); - Specificity – 85.3 (73–79); For AHI ≥ 30 (27.6 cut off point for portable); - Sensitivity – 88.6 (78–99); - Specificity – 90.9 (82–99); For PSG AHI ≤ 10:; - Automatic scoring in portable: 5.3±5.1; ♦ PSG: 3.1 ± 2.1 Portable:; - Manual scoring in portable: 36.4±23.4; ♦ PSG: 41.8 ± 27.7; - Sleep Efficiency:; ♦ (PSG)/(( 14 )) : for AHI< 10: 79.3 (12.7); for AHI ≥ 10 80.6 (14.4); total: 80.4 (14); ♦ [underlined: Portable]: NR | Bland-Altman Plot:; - Difference between manual and automated analysis of the portable only; - Automatic: −23.98 ± 30.2 (distribution of points is straight downward); - Manual: −3.98 ± 14 (distribution of points toward the horizontal line); ROC:; - Discriminatory ability of the manual scores was greater than that observed with automatic scores for all AHI cutoff points (≥ 5, ≥ 10, ≥ 15, ≥ 20, ≥ 30); - Best results were achieved at ≥ 5 with manual scoring (ROC: 0.97.6) clearly superior to automatic scoring (ROC: 0.828); - Best cut off point for the portable=6.7

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: 8% (7/86) Reasons:; - Sleep time <240 minutes; - Lack of thermister signal; - Incomplete recording due to technical problems for storing data in the computer; Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable : Y; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: N; - Portable scoring fully described: N; Evidence Level Score: II Quality Level Score: C Grade: Fair | Conclusions:; - The MERLIN device is a useful diagnostic approach for the initial assessment of adult patients with clinical suspicion of sleep apnea syndrome; - Manual scoring is clearly better than automated scoring; - 90 to 96% of patients were correctly classified by portable using its best cut-off points in its manual index of respiratory events; - For patients incorrectly classified for low AHI cut-off points, discrepancy with PSG was small; - Differences were greater with regard to high cut-off points and showed the portable had a tendency to underestimate severe sleep apnea cases; Limitations:; - Small sample, made up of mostly males with a high prevalence of sleep apnea, which limits generalizing results to a non-referral population

Evidence Table 2 Dingli et al, 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Dingli K, Coleman EL, Vennelle M et al., Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome European Respiratory Journal, 2003^15^ Study Location/Sponsor: Scotland, UK/NR Type: 3 | Device: Embletta Equipment & Methodology: NR Channels: Nasal pressure detector; thoraco-abdominal movement detection, finger pulse oximeter; body position detection Flow: Canulae/pressure tranducer system Effort: Piezoelectric belts Portable Setting: In-lab; Home Mode: In-lab: NR Home: unattended Hook-up: In-lab: trained technicians; Home: patients, after 20 minute education by trained technician, written instructions, and applied sensors unsupervised Timing: In-lab: synchronous Home trial: on two separate nights, in random order within a time interval of 2–40 days | Site: Sleep center Inclusion: Possible OSAHS Exclusion: Living > 50 miles from the sleep center and immobility Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: In-lab: 40 consecutive patients Home: 61 consecutive patients Excluded: NR Entered: In-lab: 40 Home: 61 Dropout: NR Data Loss: In-lab: 1 was excluded due to technical problems as the portable only recorded 3 minutes of interpretable data In-home: 11 patients (1 due to not using equipment at all; 5 due to technical problems with the portable equipment; and 5 with no reasons reported) Analyzed: In-lab: 39 Home: 50

Demographics | PSG Euipment | PSG Interpretation | Portable Interpretation
[underlined: In-lab/Home] Males: 33/47 Mean BMI: 32/31 Range: NR SD: ± 6 kg/m2 Mean Age: 46/50 Range: NR SD: ± 10 years/± 11 years % Non-White: NR Prevalence of OSA by PSG: AHI<10:5.3±0.9 AHI≥10<20:13.8±0.7 AHI≥20:56.3±7.7 Ave AHI:; - In-lab:35 h^−1^; - Home: 29 h^−1^; SD: NR PSG AHI>15: 76% Comorbidities: NR | Setting: Sleep Lab Equipment & Methodology: Compumedics, applied by trained technicians Channels: Sleep monitoring through 2 frontal unipolar, unilateral (FP1-LEOG, FP2-REOG) and bipolar sentral/occipital (CZ-PA) EEG, 2 submental EMG, bilateral tibial EMG and a body position detector; 3-lead ECG; respiration monitoring, thoraco-abdominal movement detection, a digital microphone for snoring detection, and a pulse oximeter Flow: thermister Effort: Two inductance plethysmographic belts | Scoring: By same observer as portable Blinding: To patient's identity or portable data or results Criteria for Excluding Data: NR Qualifications: NR | Scoring:; - Both in-lab and home study were scored by same observer as PSG; - Home: manual scoring of A+H by changes in nasal pressure and thoraco-abdominal movement; and manual scoring of A+H by nasal pressure alone; and automatic scoring of A+H; Blinding: To patient's identity or PSG results Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Apneas: complete cessation of airflow; - Hypopneas: reduction in thoraco-abdominal movement ≥50% for ≥10 s; during synchronous study, portable scored it as a reduction in the nasal pressure amplitude of ≥50% for ≥10s; - <10 (A+H)/h^−1^ in bed = Not OSAHS; 10 to 20 (A+H)/h^−1^ in bed = Possible OSAHS; ≥20 (A+H)/h^−1^ in bed = OSAHS; (manual portable scoring); AHI:; - # of apnoeas and hypopneas AND; - For PSG: After sleep onset by total sleep time; - For Portable: by total time in bed (started after respiration settled down to a rhythmic stable pattern); Apnea Index:; - Using hypopnea scoring based on nasal pressure changes alone, 1 patient with PSG (A+H >15 h^−1^) would have been scored normal by portable; AHI/RDI:; - Avg PSG AHI:; ♦ 35.4±5.5; AHI<10: 5.3±0.9; AHI≥10<20:13.8±0.7; AHI≥20: 56.3±7.7; - For AHI ≥15 on PSG:; ♦ 21/22 of pts with OSAHS had ≥20 (A+H/h^−1^ in bed) with manual home study scoring; - For AHI < 15 on PSG:; ♦ 9/9 had <10 (A+H/h^−1^ in bed) with manual scoring; - For AHI ≥ 15 on PSG:; ♦ 23/23 had > 20 (A+H/h-^−1^ in bed); ♦ Sensitivity – NR; ♦ Specificity – NR; - Using home A+H/hr > 20 as a positive and A+H/hr < 10 as a negative, there were no false-positives or false-negatives; - 36% of home study results were in the “indeterminate range”; Sleep Efficiency:; - Simultaneous in-lab with PSG: 76 ± 2%; - Home Patients as measured in lab: 82.0 ± 1% | Bland-Altman Plot and Scatterplots: In-lab:; - manual analysis of recordings:; ♦ kappa: 0.62; P<0.001;; - manual analysis of nasal pressure changes:; ♦ kappa: 0.57; P<0.001; Home:; - manual analysis vs PSG outcomes:; ♦ kappa: 0.54; P<0.001; During both the in-lab and home studies, agreement between PSG and automated portable analysis was poor (kappa: 0.28 and 0.10) ROC: NR

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author's Conclusions/ Limitations
Data Loss:; - In-lab: 1 due to technical problems as portable only recorded 3 minutes of interpretable data; 3 due to technical problems in the nasal pressure recordings (not recording or not interpretable); - Home: 11 (18%) (1 due to not using equipment at all, 5 due to technical problems with the portable equipment such as plugging, batteries or software, for 5 there was no reason reported); after a learning effect from the first third, the rate dropped to 12%; Night to Night Variability: NR Cost Benefit Analyses: Portable reduce diagnostic costs by 42% if those in the diagnostic categories went straight to CPAP titration or no further investigation with only those in the possible OSAHS and failed home study groups proceeding to PSG | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: L-N; H-Y; - Random order of allocation of subjects to PSG or Portable first: Y; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable : L-Y; H-N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: L-N; H-Y; Evidence Level Score: I Quality Level Score: A Grade: Good | Conclusions:; - Using three diagnostic categories, 32 of 50 patients from the in-lab study were correctly categorized, but 18 of 50 fell into the “possible OSAHS” category in which further study might be indicated (of those, 15 had PSG's of ≤15); - All 34 with >15 (A+H/h^−1^) on the portable had AHI's >15; - 3/16 of <15(A+H/h^−1^) on portable had AHI's <15; - The mean difference between (A+H)/h^−1^ in bed was 2± 5h with a close correlation between the results of the two studies (rho=0.98, p<0.001) but with AHI the difference was 8± 16h^−1^ but when those with >40 per hour were excluded, the mean difference was 2± 5h; - Use of nasal pressure signal as the sole indicator of hypopneas will result in unscorable traces in ~8~ of studies; - The automated scoring software did not relate closely to manually scored results; Limitations:; - Small number of subjects; - Variance in home study could be due to night-to-night variation

Evidence Table 3 Marrone et al., 2001: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Marrone O, Salvaggio A, Insalaco G et al. Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Archives for Chest Disease, 2001^9^ Study Location/Sponsor: NR (assume Italy)/NR Type: 3 | Device: POLYMESAM Equipment & Methodology: A recorder to which multiple sensors are linked for the detection of signals (listed below) Channels: Oxyhemoglobin saturation by finger sensor; heart rate from 3 ECG chest electrodes; snoring sound by microphone on thyroid cartilage; body posture; oronasal airflow; thoracic and abdominal movements; and limb activity or CPAP Flow: Three-fold thermocouple sensor for both nostrils and mouth Effort: Stretch belts Portable Setting: Sleep lab Mode: Attended but technician not allowed to visualize signals of portable Hook-up: NR, assume technician Timing: Simultaneous | Site: Sleep Lab Inclusion: Patients referred to sleep laboratory with suspected sleep apnea syndrome Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 50 consecutive Excluded: NR Entered: NR Dropout: NR Data Loss: NR Analyzed: 50

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 40 Mean BMI: 32.7 Range: NR SD: ±6.1 kg/m^2^ Mean Age: 49.6 Range: NR SD: ±10.2 years % Non-White: NR Prevalence of OSA by PSG: RDI>10: 84% (42/50) Ave RDI: NR SD: NR Comorbidities: NR | Setting: Sleep Lab Equipment & Methodology: Somnostar Channels: 2 EEG (C3-A2, O1-A2); right and left EOG; submental EMG; oronasal airflow; thoracic and abdominal movements; oxyhemoglobin saturation; ECG; and body posture Flow: Thermocouple Effort: Piezoelectric belts | Scoring: NR Blinding: Separate scorers blinded to paired results Criteria for Excluding Data: NR Qualifications: NR | Scoring: Automated, but raw data visualized and manually corrected, with the exception of ECG that can only be visualized as heart rate Blinding: Separate scorers blinded to paired results Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Central apneas: absence of airflow for at least 10 s associated with the lack of any thoraco-abdominal movement; - Obstructive apneas: absence of airflow for at least 10 second, associated with the persistence of thoraco-abdominal movement; - Hypopneas: discernible reductions in the airflow signal for at least 10 seconds, associated with a decrease in oxyhemoglobin saturation by at least 4%; - Portable: all events normalized to per hour of time in bed vs PSG which used total sleep time; - Sleep efficiency: total sleep time divided by total time in bed times 100; - OSA: AHI≥10; - AH/TIB: number of apneas and hypopneas per hour of time in bed; Apnea Hypopnea Index: AH/TIB ≥5:; - Sensitivity – 100.0; - Specificity – 71.4; - Positive predictive value: 95.5; - Negative predictive value: 100; AH/TIB ≥10:; - Sensitivity – 95.2; - Specificity – 100.0; - Positive predictive value: 100.0; - Negative predictive value: 80.0; Desaturation Index: Lowest oxyhemoglobin saturation during sleep was 75.1±11.2%; time spent in SaO_2_ below 90% was 25±24% Sleep Efficiency: 65 ± 20.9% | Bland-Altman Plot:; - Good agreement between apnea/ hypopnea per time in bed; central apnea per time in bed; mixed apnea per time in bed and mean apnea/hypopnea duration; - Lower obstructive apnea per time in bed was reflective of a higher hypopnea per time in bed; ROC: NR

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Level Score:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level Score:; - Prospective study: N; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (≥ 90% of those entered): N; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: Y; Evidence Level Score: I Quality Level Score: D Grade: Poor | Conclusions:; - The number of central, obstructive, or mixed apneas, hypopneas and total number of ventilatory disorders per hour of time in bed were significantly correlated; - Obstructive apnea per time in bed was lower with the portable device; - Due to low sleep efficiency, all indices calculated on total sleep time were on average 35% higher than those calculated on time in bed, this resulted in significantly higher total sleep time rates with respect to total time in bed rates; Limitations:; - When using cardiorespiratory monitoring the rate of disordered breathing events are calculated per hour of time in bed and not total sleep time

Evidence Table 4 Reichert et al., 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Reichert JA, Bloch DA, Cundiff E et al. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system and polysomnography. Sleep Medicine, 2003^16^ Study Location/Sponsor: California, USA/Sequoia Hospital Pulmonary Research Fund Type: 3 | Device: NovaSom QSG Equipment & Methodology: A bedside unit and a patient module worn on the patient’s wrist and three body sensors: airflow, finger oximeter and respiration effort Channels: 5: nasal and oral airflow, oxygen saturation, heart rate, respiration effort and snoring sound intensity Flow: Nasal and oral airflow using sound Effort: NR Portable Setting: In-lab; Home Mode: Unattended Hook-up: Home: Patient picked up system from sleep lab and told to use it for 3 nights but received no instructions on how to use it but given a Quick Guide and instructional video and 24 hour help line telephone number Timing:; - In-lab: simultaneous; - Home: within 7 days before or after PSG (half of patients were done before PSG, half after) | Site: Sleep lab Inclusion: Adults suspected of sleep apnea referred to the clinic for PSG Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | [underlined: Eligible]: 51 consecutive adults Excluded: NR Entered: 51 Dropout: NR Data Loss:; - Home: 3 from unuse of portable system; 3 from faulty memory chip in portable; - In-lab: 3 to technician procedure error; 4 due to error made when data was being uploaded; [underlined: Analyzed]: 45 completed (Note: 40 of 44 in-lab recordings were split night studies)

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 38 Mean BMI: 30 Range: 22-47 SD: ± 1.0 Mean Age: 52 Range: 30-83 SD: ±2.1 % Non-White: NR Prevalence of OSA by PSG: AHI>15: 20/44 Ave RDI: NR SD: NR Comorbidities: NR | Setting: Sleep lab Equipment & Methodology: Grass polygraph and recorded by Sandman Diagnostics System Channels: 2 EEG, EOG, submental EMG, ECG, anteior tibialis EMG, diagphragmatic EMG, microphone (snoring sounds), end tidal CO2, nasal –oral airflow, abdominal and thoracic respiration, and oximetry Flow: Thermocouple Effort: Piezo sensors | Scoring: Manual Blinding: Technologist blinded Criteria for Excluding Data: NR Qualifications: Trained | Scoring: Automated Blinding: For in lab: Technologist blinded to portable signals during recording and scoring of data Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Apnea: cessation of airflow for 10 s or longer; - Hypopnea: ≥ 50% reduction in airflow for 10s or longer accompanied by a ≥ 2% decrease in oxygen hemoglobin saturation; - AHI >15: positive for OSA (Home study data is averaged across the three nights); - AHI PSG: based on total sleep time; for Portable: based on total recording time; for home study it is the average across all nights of home testing; AHI/RDI:; - Avg PSG: NR; - Portable: NR; For AHI ≥ 15 (overall agreement 0.932); - Sensitivity – In lab: 95% ± 5% ;Home: 91% ± 6%; - Specificity – In lab: 91% ± 6% ; Home: 83% ± 8%; - Kappa: 0.864 ± 0.076 SE; - LR+ 5.35, LR- 0.11 (calculated by reviewer); - Positive predictive value – In lab: 91% ± 6% ; Home: 83% ± 8%; - Negative predictive value – In lab: 96% ± 4% ; Home: 91% ± 6%; For RDI>5:; - Home vs PSG Lab: Kappa: 0.734 ± 0.101 SE | Bland-Altman Plot: The differences between the PSG and home study are mainly clustered around the 0 horizontal line, with a heavier concentration for those when the mean AHI is less that 20. There were larger differences when the AHI was > 20 (As interpreted by the reviewer, though the mean difference appeared to be small, the limits of agreement estimated by ± 2 standard deviations (SD) were ± 60 events per hour) ROC: NR

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: 3 subjects used home portable less than three nights; 3 home studies had a faculty memory chip; 3 in-lab studies had technician procedure error and 4 in-lab studies had an error when data was being uploaded. Night to Night Variability: NR Cost Benefit Analyses: NR | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: Y; - Random order of allocation of subjects to PSG or Portable first: L-NA; H-N; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: N; - Portable scoring fully described: N; Evidence Level Score: II Quality Level Score: B (lab) D (home) Grade: Fair (lab) Poor (home) | Conclusions:; - In populations suspected of having OSA, the portable demonstrated acceptable sensitivity and specificity both in the lab and self-administered in the home when compared to PSG; - The portable was capable of accurately determining negative cases in both the lab and the home; - There were 4 false positives in the home, but if the cutoff was changed to 18, they would all be eliminated; - Two subjects had false negatives, but one of the subjects had all hypopneas, and the effect could be due to night-to-night variability; - The in-home test corrobated the diagnoses and gave an indication of severity; Limitations:; - In lab night and home nights were not the same; - Patient population did not allow testing whether the sensitivity would remain high in subjects with a low probability of OSA; - Portable does not have a body position sensor, therefore position-related apnea can not be determined; - The portable does not record EEG therefore sleep onset is not definitely known and sleep staging is not possible

Evidence Table 5 Ayas et al., 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Ayas NT, Pittman S, MacDonald M et al. Assessment of wrist-worn device in the detection of obstructive sleep apnea Sleep Medicine, 2003^13^ Study Location/Sponsor: Brigham and Women’s Hospital, Boston, MA Type: 4 | Device: Watch_PAT100 (WPAT100) Equipment & Methodology: Uses a finger mounted optic/pneumatic sensor that eliminates venous pulsations and continuously measures the pulse volume of the digit Channels: 4: Peripheral arterial tone (PAT), oxygen saturation, heart rate, actigraphy Flow: NR Effort: NR Portable Setting: Sleep lab Mode: NR Hook-up: NR Timing: Simultaneous | Site: Sleep Center Inclusion: Adults suspected of having sleep apnea and persons without suspected sleep apnea recruited from advertisements Exclusion: Individuals using home oxygen, medically unstable, or using medications that block the alpha receptor Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 30 (25 with suspected sleep apnea, 5 healthy volunteers responding to a flyer) Excluded: NR Entered: NR Dropout: NR Data Loss: NR Analyzed: 30

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 19 Mean BMI: 31.0 Range: NR SD: ± 7.6 kg/m2 Mean Age: 47 Range: 24.3–66.6 SD: ± 14.8 % Non-White: NR Prevalence of OSA by PSG: RDI>15: NR Ave RDI: NR SD: NR Comorbidities: NR | Setting: In-lab Equipment & Methodology: ALICE3 digital PSG system Channels: EOG, ECG, submental and tibial EMG, EEG (C2-A1, C3-A2, O1-A2, O2A1), arterial oxygen saturation, snoring intensity, nasal-oral airflow, chest and abdominal motion Flow: Thermistor and nasal pressure Effort: NR | Scoring: Manual by single technologist Blinding: To portable data Criteria for Excluding Data: NR Qualifications: NR | Scoring: Automated Blinding: NR Data Quality Categorized: Respiratory events were detected during sleep, per actigraphy, using a combination of PAT signal attenuation, desaturation on pulse oximetry, and changes in heart rate. Criteria: ≥30% PAT amplitude reduction together with a pulse rate acceleration of 10% or ≥ 30% PAT amplitude reduction together with a 3% oxyhemoglobin desaturation, or a 4% oxyhemoglobin desaturation Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Apnea: scored if airflow was absent for 10 s; - Hypopnea: if airflow was reduced by 50% or a lesser extent in association with a desaturation of 3% or anarousal; - AHI: agreement if both were greater than 40 events per hour or if AHI was; < per h on PSG and portable was within 10 events per h of AHI; AHI/RDI:; - Avg PSG: 23 + 23.9 events per hour, range: 1–94; - Portable: 23 ± 15.9 events per hour, range: 6–69; - Corr: Pearson’s coefficient= 0.87, P <0.001; Other Indices: PLM index: mean=6 Sleep Efficiency: NR | Bland-Altman Plot: At lower levels of AHI, the portable tended to overestimate disease severity, while at higher levels of AHI, the portable underestimated severity ROC:; - Set thresholds at 10,15,20 and 30 events per hour; - For all, the AUC was greater than 0.86; - Optimal combinations of sensitivity/specificity:; ♦ >10: 82.6/71.4; ♦ >15: 93.3/73.3; ♦ >20: 90.9/84.2; ♦ >30: 83.3/91.7

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable : N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: N; - Portable monitor methodology fully described: Y; - Portable scoring fully described: N; Evidence Level Score: II Quality Level Score: D Grading: Poor | Conclusions:; - Portable tended to overestimate events when PSG AHI was in the lower range (a PSG AHI of 0 would result in a portable of 5.6; 5, 9.5; 10, 13.3) but this may due to portable detecting events that were missed by standard scoring criteria or sleep fragmentation (arousals); - As PSG AHI increased, the portable tended to underestimate AHI (30, 28.7; 60, 51.8) because portable had more difficulty detecting each individual event when such multiple events occurred over a brief time period; Limitations:; - Did not test Watch_PAT in the home, so performance under these conditions is not known; - Can’t identify patients with other disorders of sleep that lead to substantial sleep fragmentation and arousals; - Device does not measure airflow so can not differentiate hypopneas from apneas; - Small sample, one sleep center; - Did not perform an event-by-event analysis of portable vs PSG AHI

Evidence Table 6 Bar et al., 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Bar A, Pillar G, Dvir I. Evaluation of a portable device based on peripheral arterial tone for unattended sleep studies. Chest, 2003^14^ Study Location/Sponsor: Haifa, Israel/Itamar Medical Ltd. Type: 4 | Device: Watch PAT100(WP100) Equipment & Methodology: Portable device based on peripheral arterial tone (PAT) signal and designed for unattended home sleep studies; battery powered console unit mounted just above the wrist and two finger mounted probes Channels: 4: actigraphy, peripheral arterial tone (PAT), oximetry, and pulse rate (derived from PAT signal) Flow: NA Effort: NA Portable Setting:; - In-lab; - Substudy in Home; Mode:; - In-lab: NR; - Substudy in Home: unattended; Hook-up:; - In-lab: NR; - Substudy in Home: patient; Timing:; - In-lab: simultaneous; - Home: two additional nights | Site: Sleep Lab Inclusion: Referred adults with suspected OSAS; home study only: within 30 mile range of sleep laboratory Exclusion: Permanent pacemaker, nonsinus cardiac arrythmias, peripheral vasculopathy or neuropathy, severe lung disease, status postbilateral cervical or thoracic sympathectomy, finger deformity that precludes adequate sensor application, use of adrenergic receptor blockers (24h washout period required) and alcohol or drug abuse during the last 3 years Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 69 consecutive subjects referred to clinic and 33 healthy volunteers Excluded: NR Entered:; - In-lab: 102;; - Substudy in Home: 14 (subset of in-lab); Dropout: 0 Data Loss:; - In-lab: 3 studies: 2 PSG studies had synchronization failure; 1 portable had valid sleep time <1.5 h; - Substudy in Home: 3 of 28 portable studies due to technical failure but were repeated successfully; Analyzed:; - In-lab: 99; - Substudy in Home: 28

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 78 Mean BMI: 26.8 Range: NR SD: ±5.5 Mean Age: 41.4 Range: NR SD: ±15.2 % Non-White: NR Prevalence of OSA by PSG: 67.6% (69/102) plus 33 normal volunteers Comorbidities: 20% hypertension 4% coronary heart disease | Setting: Sleep Lab Equipment & Methodology: Embla Channels: 2 EEG (C3-A2, O2A1), right and left EOG, chin EMG, arterial oxygen saturation, nasal-oral airflow, ECG, chest and abdominal wall motion, bilateral anterior tibialis EMG, and body position Flow: Thermisters and nasal pressure Effort: Piezo electrodes | Scoring: Manual Blinding: To portable data and results Criteria for Excluding Data: AASM criteria; - PSG sleep time<1.5h; - Technical failure of synchronizing the PSG to the WP100; - Poor quality of the PSG recording; Qualifications: NR | Scoring: Automated (proprietary algorithm) Blinding: To PSG data Data Quality Categorized: NR Criteria for Excluding Data:; - Technical failure of synchronizing the PSG to the WP100; - WP100-related rejection (valid sleep time < 1.5 h); Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Apnea/hypopnea event: airflow amplitude but with the presence of arousal of oxygen desaturation of at least 3%; - PSG RDI: # of apnea/hypopnea per hour of sleep; - OSA diagnosis: PSG-RDI>10; AHI/RDI:; - In-lab portable versus PSG:; ♦ Corr: r=0.88, P<0.0001, n=99; - Portable in-lab versus portable in-home:; ♦ Mean of two nights of home study: Corr: r=0.89, P<0.001, n=14; ♦ Each night of home study: Corr: r=0.94, P<0.001, n=14; - For RDI ≥ 20 (as calculated by reviewer):; ♦ PSG: 9; ♦ Portable: 7/9; ♦ Sensitivity: 78%; ♦ Specificity: 60% (two false-positives) (1 false positive had PSG RDI of 19 and if considered correctly classified, then sensitivity would rise to 80% and specificity to 75%); ♦ LR+: 3.2; LR-: 0.27 | Bland-Altman Plot: There was a slight tendency for the portable to underscore events in the mild range of OSAS and to overscore events in the severe range ROC:; - With the RDI threshold set at 10, the diagnostic threshold, the area under the curve is 0.82 (P=0.0001) showing the potentially high sensitivity and specificity in diagnosing OSAS; - With the RDI threshold set at 20, when CPAP therapy is indicated, the area under the curve is 0.87 (P=0.0001) showing the potentially high sensitivity and specificity in diagnosing OSAS of a severity requiring treatment

Data Loss/Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: In-lab: 3 of 102 Home: 3 of 28 Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: Y; - Reference standard done on all subjects:; ♦ In Home Substudy 3 tests were repeated: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: L-N; H-Y; - Random order of allocation of subjects to PSG or; ♦ Lab: NA; ♦ Home: N; - Low data loss ≤ 10% of flow/SaO_2_/ EEG as applicable: L-Y; H-N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: N; Evidence Level Score: II Quality Level Score: C (lab) C (home) Grade: Fair (lab) (home) | Conclusions:; - The in-lab portable comparison with PSG results were well correlated with good efficacy for both OSAS diagnosis and therapy indication; - The in-lab portable results were highly reproducible in the home sleep studies, for laboratory versus home and between the two home sleep studies; - Device reliability is demonstrated by low rejection rates; Limitations:; - Study population consisted of patients with snoring/sleep apnea syndrome and healthy volunteers; - Did not evaluate the device for upper airway resistance syndrome

Evidence Table 7 Golpe et al., 2002: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Golpe R, Jimenez A, Carpizo R. Assessment of sleep apnea/hypopnea syndrome. Chest, 2002. 122(4); 1156–1161^11^ Study Location/ Sponsor Spain/NR Type: 4 | Device: Apnoescreen-I Equipment & Methodology: NR Channels: Body position, wrist actimetry, pulse rate, arterial oxygen saturation Flow: Oronasal airflow with thermistor Effort: NA Portable Setting: Home Mode: Unattended Hook-up: 50/50 split:; - G1: by Technician at home; - G2: by patients after 15–20 minute training period at the hospital and written instructions; Timing: portable done first (PSG done within 30 days) | Site: Sleep lab Inclusion: At least 2 of the following: loud snoring, observed apneas, daytime drowsiness; and judged by author to be require sleep study Exclusion: Physical or mental impairment that precluded use of equipment Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 59 invited Excluded: 0 Entered:; - 55, randomly assigned; ♦ G1: 28; ♦ G2: 27; Dropout: NR Data Loss:; - 11 (20%) home studies produced no interpretable data; ♦ G1: 2 (poor signals in flow channel); ♦ G2: 9 (3 where patient failed to turn on equipment and 6 due to poor signals or artifacts in the flow channel); Analyzed: 44

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 96% Mean BMI: 30.3 Range: NR SD: 4.6 Mean Age: 52.7 Range: NR SD: 13.3 % Non-White: NR Prevalence of OSA by PSG: RDI>10: 23/44 Ave RDI: NR SD: NR Comorbidities: NR | Setting: Sleep lab Equipment & Methodology: Medelec Channels: 14: EEG, Chin electromyogram, electro-oculogram, ECG, tibial electromyograms, oxygen saturation with a finger sensor, body position, snoring, oronasal, and thoracoabdominal movement Flow: Oronasal by thermistor Effort: Piezo-electric bands | Scoring: Manual Blinding: Investigator blinded to home study results and other investigators results Note: Investigators had intake interview results available to them Criteria for Excluding Data: NR Qualifications: NR, but one of the authors, an MD was an investigator | Scoring: Automated and manual (through counting episodes on the video screen graphic display-which does not measure with accuracy the Type of desaturation) Blinding: Investigator blinded to in-hospital study results and other investigators results Note: Investigators had intake interview results available to them Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR, but one of the authors, an MD was an investigator

Comparison of Results | Special Statistics
Definitions:; - Apnea: complete cessation of airflow ≥ 10 s; - Hypopnea: discernable reduction in respiratory airflow ≥ 10s and SaO_2_ decreased ≥ 4% oxygen saturation and/or arousal (thermisters only allow qualitative); - PSG AHI: average # of episodes of apnea and hypopnea per hour of sleep; - Portable: average # of episodes of apnea and hypopnea divided by the registry time and sleep time in hours; - Manual respiratory index per hour of registry time (mRDI-r) ≥ 10 = SAHS; PSG SAHS: n=23 (including “doubtful“ home studies); - Home study: 18/23 in agreement; - False Negatives: 1/23; PSG No SAHS: n=21 (including “doubtful“ home studies); - Home study: 15/21 in agreement; - False Positives: 3/21; PSG SAHS: n=19 (without “doubtful“ home studies); - Home study: 18/19 in agreement; - False Negatives: 1/19; PSG No SAHS: n=18 (without “doubtful“ home studies); - Home study: 15/18 in agreement; - False Positives: 3/18 | Bland-Altman Plot: Horizontal lines were drawn at the mean difference: −4.2±1.96 the SD of the difference. The plot shows a large spread for the Type of agreement and the text notes that there were 5 cases were outside the limit of agreement ROC: There were no differences between the areas under the curves when the respiratory disturbances indexes were referred either to registry time or to the estimated sleep time. The manual respiratory disturbance (either referred to the registry time or to the estimated sleep time) seemed the most useful indexes for the diagnosis of SAHS, as they had the larger area under the ROC curve, but the values obtained for the indexes were too similar to assess if the differences was significant. No other curve details presented AUC: 0.89 for manual scoring and 0.86 for automated scoring. (Reviewer visual interpretation of ROC found that best sensitivity was 90% and best specificity was 80% which calculated to a LR+ of 4.5 and an LR- of 0.125)

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: G1: 7% G2: 33% Night to Night Variability: NR, but mentioned Cost Benefit Analyses: Home studies with a technician setup of the equipment were less expensive (because of the high percentage of faulty studies with patient own setup of sleep recording devices) | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: Y; - Random order of allocation of subjects to PSG or Portable first: N; - Low data loss ≤ 10% of flow/SaO_2_/EEG asapplicable : N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: N; Evidence Level Score: I Quality Level Score: C Grade: Fair | Conclusions:; - Home studies are a viable form of diagnosing SAHS because they are more economic even with relatively high %s of faulty or inconclusive recording that lead to repeat studies. Technician intervention still is less costly than in-hospital PSG.; - Agreement on the clinical decision on whether to treat the patient with CPAP based on the home study result was 77% (34 of 44 cases); Limitations:; - Did not analyze the long-term results of CPAP therapies; - Social Type of population should be taken into account; - Home study overestimated the severity of SAHS. There were 3 false negatives and 3 false positives, though authors suggest the latter 3 could be false-negatives from the PSG or night-to-night variability.; - Relative complexity of home study systems are useful for rural areas but these patients may not be as familiar with electronic devices

Evidence Table 8 Gurubhagavatula et al., 2004: Study Design

Reference | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Gurubhagavatula I, Maislin G, Nkwuo JE et al. Occupational screening for obstructive sleep apnea in commercial drivers. American Journal of Respiratory Care, 2004^20^ Study Location/Sponsor: Philadelphia, PA, US/Trucking Research Institute of the American Trucking Institute, funded by the Federal Motor Carriers Safety Administration; and Nellcor, Inc., and Ohmeda, Inc provided partial support Type: 4 | Device: NR Equipment & Methodology: Nocturnal Pulse Oximetry Channels: 1: oximetry Flow: NR Effort: NR Portable Setting: In-lab Mode: NR Hook-up: NR Timing: Simultaneous | Site: Philadelphia, PA Inclusion: People with commercial drivers licenses within a 50 mile radius of Philadelphia, PA (random selection) Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: 0.49(0.21) | Eligible: 4,286 questionnaires mailed Excluded: Non-responders to the questionnaire Entered: 1,329 enrolled, stratified into high and low risk for apnea. Performed oximetry and PSG in 44.8% (247/551) in high risk group and 20.4% (159/778) in low risk group Dropout: NR Data Loss: NR Analyzed: 1,329

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 93.5% Mean BMI: 28.4 Range: SD: ± 4.85 Approximately half of the sample was obese (≥30 kg/m^2^) Mean Age: 44.4 Range: SD: ± 11.2 % Non-White: 15% Prevalence of OSA by PSG: (weighted sample) AHI ≥ 5: 28.1% AHI ≥ 30: 4.7% Ave RDI: NR SD: NR Comorbidities: Current smoking: 30.9 % (±2.5) Any smoking: 61% (±2.6) | Setting: In-lab Equipment & Methodology: NR Channels: NR Flow: NR Effort: NR | Scoring: NR Blinding: To other results Criteria for Excluding Data: NR Qualifications: NR | Scoring: NR Blinding: To other results Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions: Any apnea: AHI≥5 (upper bound of 0.9, lower bound 0.2 and desaturation threshold of 5 events per hour); Severe apnea: AHI≥30 (upper bound of 0.9, lower bound 0.3, desaturation threshold of 10 events per hour) AHI/RDI: Oximetry versus PSG:; - For AHI ≥ 15; ♦ Sensitivity – .89 (0.738–1.000); ♦ Specificity – .95 (0.897–0.951) | Bland-Altman Plot: NR ROC:; - Multivariable prediction plus oximetry with 0.9,0.3 and 10± cut points had an area under the curve of 0.937 (0.936–0.939) and Likelihood Ratio of 0.100 (0.0350.323); - Oximetry alone prediction with a 14.9 cut point had an area under the curve of 0.971 (0.945–0.992) and a Likelihood Ratio of 1.22 (0.000–0.283)

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NR Cost Benefit Analyses: Only in regard to motor vehicle crashes | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: N; - Reference standard done on all subjects: Y; Quality Level:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (≥ 90% of those entered): N; - PSG methodology fully described: N; - Portable monitor methodology fully described: N; - Portable scoring fully described: N; Evidence Level Score: II Quality Level Score: D Grade: Poor | Conclusions:; - The oximetry enhanced (symptoms + BMI) approach had a sensitivity of 89% and specificity of 95% and had better discriminatory power (negative likelihood, 0.29); - Neither oximetry strategy excluded drivers with AHI≥5 with acceptable sensitivity; - For drivers with AHI≥30, the enhanced oximetry had a 91% sensitivity and specificity and yielded a 0.10 likelihood ratio; PSG was not necessary in 86%, the false-positive rate was 8.9% and the false-negative rate was 0.5% and the negative predictive value of 99%; oximetry did not improve the negative likelihood ratio, thus to exclude severe apnea, the enhanced oximetry approach is optimal; - For any apnea, oximetry offered minimal additional predictive advantage with a negative likelihood ratio of 0.29; Limitations:; - Validated strategies in the same cohort in which it was derived which may artificially inflate its predictive value; - Oximetry was not conducted in the home

Evidence Table 9 Liesching et al., 2004: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Liesching TN, Carlisle C, Marta A et al. Evaluation of the accuracy of SNAP technology sleep sononography in detecting obstructive sleep apnea in adults compared to standard polysomnography. Chest, 2004^19^ Study Location/Sponsor: Rhode Island, USA/NR Type: 4 | Device: SNAP technology Equipment & Methodology: Home system consists of a microphone cannula device that is placed on the subject’s upper lip during sleep Channels: Oronasal respiratory sound and airflow Flow: Monitors positioned over the oral and nasal apertures Effort: NR Portable Setting: Home Mode: Unattended Hook-up: Patient Timing: Mean followup time between the two studies was 5 months (range 2 to 10 months) | Site: Sleep Clinic Inclusion: Referred to the sleep center for PSG; prior receipt of SNAP technology testing in past 2 years based on referral of primary care physician for suspected sleep apnea (per retrospective medical record review) Exclusion: Not having had SNAP technology testing in past 2 years; patients who had SNAP testing but refused subsequent PSG Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 39 Excluded: 3 refused further diagnostic evaluation or workup Entered: 36 Dropout: 4 were referred for split-night studies at request of physician Data Loss: 1 SNAP test did not provide an AHI value Analyzed: 31

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 14 of 31 Mean BMI: 31.6 kg/m^2^ Range: 24–44 SD: NR Mean Age: 50.3 Range: 29–77 SD: NR % Non-White: NR Prevalence of OSA by PSG: AHI>5: 45% Ave RDI: NR SD: NR Comorbidities: NR | Setting: Sleep Disorders Center Equipment & Methodology: NR Channels: EEG, EOG, submental EMG, chest and abdominal impedence, intercostals EMG, airflow, SaO_2_ through pulse oximetry, ECG Flow: Thermisters and nasal pressure transducer Effort: Plethysmography | Scoring: Manual Blinding: To results of SNAP studies Criteria for Excluding Data: NR Qualifications: Physician trained in sleep medicine | Scoring: NR Blinding: NR Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - PSG: apnea/hypopnea event: clear decrease (>50%) from baseline in the amplitutde of the nasal pressure transducer signal during sleep, or by a clear amplitude reduction in the nasal pressure transducer signal during sleep that does not reach the >50% criterion but is associated with either an oxygen desaturation of >3% or an arousal, in either case the event must last ≥10 s; - Apnea in portable: cessation of sound for > 10 s; - Hypopnea in portable: sound amplitude is reduced to <25% of the baseline (i.e., quiet respiration) amplitude for at least 10 s. Baseline sound can not be secondary to snoring; or reduction in sound is part of a cyclical change in amplitude; or respiratory rate is not significantly reduced during event; - AHI: total number of apneas and hypopneas per hour of sleep (PSG) per hour of the study (Portable); - OSA: PSG ≥ 5 events per hour; mild: 5 to 15; moderate: 15 to 30; severe: >30; AHI/RDI:; - Mean PSG: 21.2±21.5; Median: 11.5 per hour; - Portable: 19.8±14.8; Median: 15.8 per hour; ♦ P=0.42; - Corr: Kappa: 0.23 (p=0.008); - Portable accurately assessed true severity in 38.7% (12/31); 54.8% (17/31) accurately predicted AHI within 10 events per hour; 45.2% (14/31) the difference was greater than 10 events per hour; - Of 8 normal PSG results, the portable rated these studies as 6 mild, 1 moderate, and 1 severe, or a specificity of 0%. Using only the moderate and severe OSA studies from the portable, the specificity increases to 75%.; - 1 false negative by the portable was classified as severe by the PSG.; - Including all false positive cases in the specificity, the LR+ is 0.91 (calculated by reviewer); - For the PSG, normal patients misclassified as moderate or severe by the portable, the LR+ is 3.64 and the LR- is 12 (calculated by reviewer); - Portable correctly classified 21 of 23 positive PSG OSA cases, or 91% sensitivity as calculated by the reviewer | Bland-Altman Plot: NR ROC: NR

Data Loss/Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: 1 of 32 (3%) Night to Night Variability: NR Cost Benefit Analyses: NR | Evidence Type:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Type:; - Prospective study: N; - Portable done outside the lab: Y; - Random order of allocation of subjects to PSG or Portable first: N; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable : Y; - High % completed (≥ 90% of those entered): N; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: N; Evidence Type Score: II Quality Type Score: D Grade: Poor | Conclusions:; - SNAP severity scores overestimated in 41.9% of patients, 25.8% of which had normal PSGs, two patients had moderate to severe AHI results from SNAP; - SNAP study underestimated severity in 19.4% (6 of 31) by at least 10 events per hour; Limitations:; - Sensitivity and specificity could not be calculated because study population did not include those patients that were tested by SNAP but not referred to the sleep clinic; - SNAP device does not measure sleep position; - Studies were not done simultaneously and in two different settings and two different methods of hook-up and monitoring

Evidence Table 10 Pillar et al., 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Pillar G, Bar A, Betito M et al. An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Medicine, 2003^17^ Study Location/ Sponsor: Technion Sleep Disorders Center, Israel/ NR Type: 4 Note: Authors Bar, Betito, Schnall, Sheffy are employees of Itamar Medical and Authors Pillar and Lavie are consultants for Itamar Medical Ltd., makers of the device | Device: Watch_PAT100 (WP100) [underlined: Equipment & Methodology:] Battery powered consol unit mounted just above the wrist. Actigraph and oximetry embedded into device Channels: 4: actigraphy, peripheral arterial tone (PAT), oximetry, and pulse rate (derived from PAT signal) Flow: NR Effort: NA Portable Setting: Sleep lab Mode: NR Hook-up: NR Timing: Simultaneous | Site: Sleep Clinic Inclusion: Referred for presumed OSAS in 61 and 7 healthy volunteers Exclusion: Permanent pacemaker, non-sinus cardiac arrhythmias, peripheral vasculopathy or neuropathy, severe lung disease, S/P bilateral cervical or thoracic sympathectomy, finger deformity that precludes adequate sensor application, use of alpha-adrenergic receptor blockers (24h washout period required), and alcohol or drug abuse during the last 3 years Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 68: 61 consecutive patients referred to clinic and 7 healthy volunteers responding to a flyer Excluded: NR Entered: NR Dropout: NR Data Loss: NR Analyzed: 68

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 54 Mean BMI: 28 Range: NR SD: ± 6kg/m2 Mean Age: 46 Range: NR SD: ± 14 years % Non-White: NR Prevalence of OSA by PSG: RDI>15: NR Ave RDI: 34 SD: ± 26 events per hour Comorbidities: 20% hypertension 4% coronary artery disease | Setting: Sleep lab Equipment & Methodology: Computerized PSG Channels: 2 EEG (C3-A2, O2A1), EOG, submental EMG, SaO_2_, nasal-oral airway, EKG, chest and abdominal wall motion, bilateral anterior tibialis EMG, and body position Flow: Thermisters and nasal pressure Effort: Piezo electrodes | Scoring: Manual Blinding: To other data and results Criteria for Excluding Data: NR Qualifications: NR | Scoring: Automatic Blinding: To other data and results Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Arousal: EEG frequency shift of ≥ 3 s ≤15 s during non-REM sleep, during REM sleep an increase in EMG was required as well, and in both cases at least 10 s of sleep prior to and following the event was required; - Arousal Index: dividing total # of arousals by # of hours of sleep; - RDI: # of apneas plus hypopneas divided by the # of hours of sleep; AHI/RDI: For RDI ≥ 20; - Sensitivity – 0.80; - Specificity – 0.79 | Bland-Altman Plot: Across a wide range of arousal frequencies, there was good agreement between the portable arousal index and the PSG arousal index Scatter Plot: Very high and statistically significant correlation (r=0.87), P<0.0001) was found between the portable autonomic arousal index and the PSG arousal index ROC: Using threshold of 20 arousals per hour of sleep the area under the curve=0.87; - Sensitivity: 0.80; - Specificity: 0.79

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): Y; - Both tests scored blindly: N; - Reference standard done on all subjects: Y; Quality Score:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: N; Evidence Level Score: IV Quality Level Score: C Grade: Poor | Conclusions:; - Automatic analysis of PAT signal derived from the WPAT100 can accurately identify arousals from sleep; Limitations:; - Took place in a sleep lab; - Aimed at detecting sleep fragmentation but chose to compare autonomic arousals to the commonly detected EEG arousals, but PAT may be sensitive to shorter arousals (<3 s); - Population was made up of patients with snoring/sleep apnea syndrome and a few healthy volunteers

Evidence Table 11 Shochat et al., 2002: Study Design

Reference | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Shochat T, Hadas N, Kerkhofs M et al. The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. European Respiration Journal, 2002^12^ Study Location/Sponsor: Israel, Germany, Belgium/ NR Type: 4 Note: P. Lavie is the scientific advisor to the company manufacturing the SleepStrip; N. Hadas is the company's R&D manager; T. Shochat is the Clinical Trials Director of the company; both P. Lavie and N. Hadas are both shareholders in the company | Device: SleepStrip™ Equipment & Methodology: Disposable sleep apnoea screener designed to aid sleep specialists or other physicians in the initial assessment of patients with suspected SAS; it is small, light weight and worn underneath the nose and above the upper lip Channels: Oral and nasal flow sensors Flow: Thermisters Effort: NA Portable Setting: In-lab Mode: NR Hook-up: NR Timing: Concomitantly | Site: Assume sleep clinics in three locations: Israel, Belgium and Germany Inclusion: Patients referred with suspicion of sleep apnea Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: NR Excluded: NR Entered: 402 (303 from Israel, 50 from Belgium, 49 from Germany) Dropout: NR Data Loss: Insufficient sleep (<5 hr): 22% (n=88); technical malfunction of portable: 8% (n=31); missing data: 1.5% (n=6); note: 11 cases had both insufficient sleep and technical malfunction Analyzed: 288 (72%) (205 from Israel, 39 from Belgium, 44 from Germany)

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: NR Mean BMI: NR Range: NR SD:NR Mean Age: NR Range: NR SD: NR % Non-White: NR Prevalence of OSA by PSG: RDI>15: NR Ave RDI: NR SD: NR Comorbidities: NR | Setting: Sleep Clinic Equipment & Methodology: NR Channels: Respiration, oronasal temperature to assess respiratory flow, oxygen saturation and percentage of sleep-time with oxygen saturation <90% Flow: NR Effort: Respiratory effort belts around the chest | Scoring: NR Blinding: NR Criteria for Excluding Data: NR Qualifications: Experienced scorers in each of the three settings | Scoring: Automatically derived scores Blinding: NA Data Quality Categorized: Criteria for Excluding Data: Device worn for less than 5 hours Qualifications: NA

Comparison of Results | Special Statistics
Definitions:; - Apneas: cessation of airflow >10 s; - Hypopneas: reduction in the amplitude for the respiratory signal of at least 50% for ≥ 10 s, followed by either a decrease in oxygen saturation or 4% or signs of physiological arousal; - PSG AHI OSA categories: >10 = mild; >20= moderate; >40= severe; Apnea Index: AHI/RDI: [underlined: Ava PSG]: NR; - Portable: NR; - Corr: Pearson r=0.73, P<0.001); [underlined: For AHI/Sscore >10]; - Sensitivity – 86%; - Specificity – 57%; [underlined: For AHI/Sscore >20]; - Sensitivity – 80%; - Specificity – 70%; [underlined: For AHI/Sscore >40]; - Sensitivity – 80%; - Specificity – 86% | Bland-Altman Plot: There is a bias of −5.8 events (Cl: −8 to −3.6 events) indicating a small overestimation of the severity of the apnoea by the portable ROC: Area under the curve ranged from 0.81 to 0.92 at the varying AHI thresholds:; - >10: 0.81 (P<0.001) Cl: 0.76–0.86; - >20: 0.84 (P<0.001) Cl: 0.79–0.89; - >40: 0.92 (P<0.001) Cl: 0.89–0.96

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author's Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NA Cost Benefit Analyses: NR | Evidence Type:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: N; - Reference standard done on all subjects: Y; Quality Type:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: NA; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (> 90% of those entered): Y; - PSG methodology fully described: N; - Portable monitor methodology fully described: N; - Portable scoring fully described: N; Evidence Type Score: IV Quality Type Score: D Grade: Poor | Conclusions:; - Though not intended as a substitute for PSG, the SleepStrip may provide initial screening information, which may be useful in both clinical and experimental settings; - Patients with medical conditions which frequently coexist with SAS, such as ischaemic heart disease, COPD and ESRD may find this technology more appealing as it can be used in the comfort of their home; Limitations:; - Not intended to replace full PSG but is for large scale screening

Evidence Table 12 Zamarron et al., 2003: Study Design

Study | Portable Device/ Implementation | Sample Selection | Study Subjects n (% of Entered)
Reference: Zamarron C; Gude F; Barcala J et al. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest, 2003^18^ Study Location/Sponsor: Barcelona, Spain/Fondo Investigacion Sanitaria; and Secretaria Xeral de Investigacion e Desenvolvemento Type: 4 | Device: Criticare 504 Oximeter Equipment & Methodology: Finger probe pulse oximetry recording Channels: SaO_2_ and heart rate Flow: NA Effort: NA Portable Setting: In-lab Mode: NR Hook-up: Assume technician Timing: Simultaneous | Site: Sleep Clinic Inclusion: Showing clinical symptoms of OSA and referred by a general practitioner Exclusion: NR Clinical Pretest Probability Distribution of Suspected Severity of OSA: NR | Eligible: 300 Excluded: NR Entered: 300 Dropout: NR Data Loss: NR Analyzed: 300

Demographics | PSG Equipment | PSG Interpretation | Portable Interpretation
Males: 78% Mean BMI: 29.5 Range: NR SD: ±5.3 Mean Age: OSA: 58.4 ± 12.1; Non-OSA: 56.6 ±12.8 Range: 21 to 84 (total) SD: NR % Non-White: NR Prevalence of OSA by PSG: AHI>10: 56% Ave AHI: 40.2 SD: ±22.4 Comorbidities:; - OSA group had significantly higher STOT, S 30—70 S, and P values than non-OSA group; - COPD, Cardiovascular Disease | Setting: Sleep Clinic Equipment & Methodology: Ultrasom Channels: EEG, EOG, chin EMG, air flow, ECG, chest wall movement Flow: Three-part thermister Effort: NR | Scoring: NR, assume manual; analyzed in periods of 30 s and during stages 1,2,3,4 and rapid eye movement Blinding: Single; independent observer of the portable data Criteria for Excluding Data: If subject has < 3 h of total sleep, study was repeated Qualifications: NR | Scoring: Automated Blinding: Single; independent observer of the PSG data Data Quality Categorized: NR Criteria for Excluding Data: NR Qualifications: NR

Comparison of Results | Special Statistics
Definitions:; - Apnea: absence of airflow >10 s; - Hypopnea: reduction of airflow for at least 10s accompanied by a ≥ 4% decrease in the saturation of hemoglobin; - Suspicion of OSA: periodogram shows a peak within the period 30 to 70 s in either SaO2 or heart rate signals; normal= absence of both signals; - PSG AHI: hourly samples of sleep; AHI ≥ 10 = OSA; Combined SaO2 and Heart Rate:; - Sensitivity: 94% (89–97); - Specificity: 82% (75–88); - PPV: 87% (81–91); - NPV: 92% (85–96); - Accuracy: 89% (84–92); - Positive Likelihood Ratio: 5.35 (3.69 – 7.78); - Negative Likelihood Ratio: 0.07 (0.03 – 0.13); - Of 10 OSA false-negatives, 40% (n=8) had severe COPD and presented no periodogram peak in 30 to 70s for both SaO2 and heart rate and thusly classified negative by portable; 2 pts had AHIs very close to limit of 10 to 15; 50% were > 65 years of age or older; - Of 12 false-positives, 30 to 50% had an AHI of slightly < 10; Other Indices:; - [underlined: SaO_2_] : 41.3% normal, 58.7% abnormal; concordance between 2 observers was 0.90 (0.86 to 0.94); - Heart Rate: 47.6% normal; 52.4% abnormal; concordance between 2 observers was 0.91 (0.87 to 0.94); - Combined SaO_2_ and Heart Rate: 49.7% normal; 50.3% abnormal; PPV: 87%(81–92); NPV: 92%(85–96); | Bland-Altman Plot: NR ROC: NR

Data Loss/ Variability/Cost Benefit | Quality Indicators | Author’s Conclusions/ Limitations
Data Loss: NR Night to Night Variability: NR Cost Benefit Analyses: As a screening tool for the diagnosis of OSA, pulse oximetry is cost effective and shows substantial accuracy | Evidence Level:; - Subjects selected consecutively or randomly (no design influence): N; - Both tests scored blindly: Y; - Reference standard done on all subjects: Y; Quality Score:; - Prospective study: Y; - Portable done outside the lab: N; - Random order of allocation of subjects to PSG or Portable first: N; - Low data loss ≤ 10% of flow/SaO_2_/EEG as applicable: N; - High % completed (≥ 90% of those entered): Y; - PSG methodology fully described: Y; - Portable monitor methodology fully described: Y; - Portable scoring fully described: Y; Evidence Level Score: II Quality Level Score: C Grade: Fair | Conclusions:; - If the test result is negative it is unlikely that the patient will receive an OSA diagnosis; - 30–70 s peaks in the periodograms in either signal had a sensitivity of 94% and 82% specificity, a PPV of 87% and NPV of 92% with respect to OSA diagnosis; Limitations: Study not designed for upper airway resistance syndrome which presents no modifications of oxygen saturation but is associated with arousals related to respiratory effort (3 patients in study had UARS)

Glossary of Terms
AHI: Apnea/Hypopnea Index
AUC: Area Under the Curve
Avg: Average
BMI: Body Mass Index
CI: Confidence Interval
COPD: Chronic Obstructive Pulmonary Disease
Corr: Correlation
CPAP: Continuous Positive Airflow Pressure
ECG: Electrocardiogram
EEG: Electroencephalogram
EMG: Electromyogram
EOG: Electro-oculogram
ESRD: End Stage Renal Disease
G: Group
h: hour
H: Home part of the study
L: Laboratory part of the study
n: number
NA: Not applicable
NR: Not Reported
OSA: Obstructive Sleep Apnea (Obstructive Sleep Apnea Syndrome (OSAS) and Sleep Apnea Syndrome (SAS) are all included under OSA)
OSAS: Obstructive Sleep Apnea Syndrome
P: Probability
PAT: Peripheral Arterial Tone
PLM: Periodic Limb Movement
PSG: Polysomnography
r: Rho
RDI: Respiratory Disturbance Index
ROC: Receiver Operator Curve
s: second(s)
SAHS: Suspected Apnea/Hypopnea Syndrome
SaO_2_: Saturated Oxygen
SAS: Sleep Apnea Syndrome
SD: Standard Deviation
Sens: Sensitivity
Spec: Specificity
vs: versus