# Data Abstraction Form

This appendix is not available from the publisher at this time.