# Acknowledgments

We thank Elise Berliner, Ph.D., Task Order Officer for the Agency for Healthcare Research and Quality for her encouragement and support throughout this project. We extend our appreciation to Loraine Monroe, the RTI-UNC Evidence-based Practice Center document preparation specialist; to Tammeka Swinson, B.A., the EPC project manager, for considerable assistance with the literature search and abstracting tasks; and to Mark Howell, RTI librarian, for help with all searches.