# Appendices

Appendix A Acknowledgments

Appendix B Data Abstraction Form

Appendix C Evidence Tables