# Results

Findings are organized according the five (A-E) policy relevant questions.

## III.A Are there limitations in diagnosing obesity in the elderly with BMI? Should another measurement be used with BMI or in place of BMI for diagnosing obesity in the elderly?

We approached the question of obesity diagnosis in the elderly by examining three facets of diagnostic tests: (1) evidence for diagnostic test validity and precision compared to referent adiposity measures, (2) evidence for associations of adiposity (as measured by different diagnostic tests) with long-term health risk, and (3) evidence that an alteration of body size with intervention is detected by the different adiposity measures.

### III.A.1 Overview of clinical diagnostic tests

In clinical practice, obesity diagnosis is typically made through anthropometric measurements. Body mass index (BMI) is the most commonly used measure, expressed as kilograms of weight divided by the square of height in meters. In the general population, it is highly correlated (0.7 to 0.8) with adult body fat. [5] Chosen for its link with an approximately 2-fold increase in mortality risk, a BMI of 30 kg./m^2^ or higher is the standard clinical measure of obesity.; [3] Other health endpoints, particularly cardiovascular events, become increasingly prevalent throughout the BMI range of 25–30. [6]

Waist circumference (WC) and waist-to-hip ratio (WHR) are measures designed to better assess central adiposity. In the general population, they are especially useful for noting increasing cardiovascular risk within a non-obese BMI range. [10, 19–22] Measuring skin fold thickness can also identify adipose individuals, but requires significant training for accuracy. [5]

### III A.2 Evidence for validity and precision of diagnostic tests for obesity in the elderly

#### Comparison between diagnostic tests and referent measures of body fat

Our searches identified 8 studies meeting our criteria for assessment of obesity diagnostic tests in elderly samples (Table 3). [10] [35, 59–64] They considered BMI, WHR, WC, and several skin-fold thickness measures. All were of fair internal validity, with problems including absent or atypical referent measures or lack of sensitivity, specificity, or predictive value calculations. None systematically evaluated adverse effects of testing. However, as these measures are entirely noninvasive the risk of harm is likely low.

Table 1 Policy-relevant tasks and Key Question approach for literature evaluation

Tasks | Key Question Approach
1. Are there limitations in diagnosing obesity in the elderly with BMI? Should another measurement be used with BMI or in place of BMI for diagnosing obesity in the elderly? | - Evaluate evidence for the validity and precision of the different diagnostic studies in the elderly?; - Assess how the different clinical measures of obesity are associated with adverse health outcome incidence; - Assess use of different adiposity measures in randomized, controlled trials for weight loss, and compare findings (efficacy, related health effects) across these measures.
2. Can weight loss be used as a surrogate for improved net health outcomes? If so, how much weight loss and over what time period of time? | - Evaluate evidence for health risk associated with obesity in the elderly; - Evaluate evidence that intentional weight loss leads to improved health outcomes.; - RCT evidence; - If RCT evidence lacking, draw inferences from general population evidence
3. Which elderly patients with obesity would experience an improved health outcome with weight loss treatment? | - Review of the characteristics of people for whom there is evidence of health risk associated with body weight; - Review of the characteristics of people for whom there is RCT evidence of benefit from weight loss.
4. Are there dietary therapies that improve net health outcomes in obese elderly? (including discussion of duration, circumstances, co-interventions, harms) | - Evaluate evidence for dietary therapy leading to weight loss in the elderly; - Evaluate evidence that intentional weight loss leads to improved health outcomes.; - Evaluate evidence that dietary obesity therapy leads to improved health outcomes
5. Are there behavioral therapies that improve net health outcomes in obese elderly? (including discussion of duration, circumstances, co-interventions, harms) | - Evaluate evidence for behavioral therapy leading to weight loss in the elderly; - Evaluate evidence that intentional weight loss leads to improved health outcomes.; - Evaluate evidence that behavioral obesity therapy leads to improved health outcomes
6. Are there surgical therapies that improve net health outcomes in obese elderly? (including discussion of duration, circumstances, co-interventions, harms) | - Evaluate evidence for surgical therapy leading to weight loss in the elderly; - Evaluate evidence that intentional weight loss leads to improved health outcomes.; - Evaluate evidence that surgical obesity therapy leads to improved health outcomes

Table 2 Search and Abstraction Summary

Search | # Abstracts from Search | References for Article Review | References Meeting Full Criteria
Diagnostic tools | 198 | 49 | 7
Longitudinal Studies | 2042 | 200 | 23
Diet: Diagnostic | 14 | 3 | 7
Diet: RCTs | 288 | 79 | 7
Diet: Reviews | 145 | 24 | 7
BT: Diagnostic | 55 | 9 | 7
BT: RCTs | 263 | 20 | 7
BT: Reviews | 151 | 14 | 7
Surgery: Diagnostic | 0 | 0 | 0
Surgery: RCTs | 9 | 1 | 0
Surgery: Reviews | 9 | 1 | 0

BT = Behavioral Therapy

No studies evaluated behavioral therapy alone in this age group, so diet and behavioral interventions were grouped.

Table 3 Diagnostic Tests for Obesity

Citation | % Female Mean Age Race | Sample | Tests | Gold Standard | Internal Validity
Deurenberg (59) | 58% Female in the larger group (sex NR by age) Race NR | A subset of 1129 healthy participants age 7–83 | BMI | BF% by bone density | Fair
Folsom (10) | 100% Female 55–69 years White | Iowa Women's Health Study Subset (n=31702): post-menopausal women had no history of CA, CHD or diabetes, and full BMI, WHR data (31,702=n) | WHR^*^ WC^†^BMI | None | Fair
Goodman-Gruen (60) | 64% Female Women: 79.4 years, Men: 80.3 years White | 385 community dwelling ambulatory participants of the Rancho Bernardo Heard and Chronic Disease Study | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio | BF % by Bioelectrical Impedence | Fair
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
| | | BMI BF%^§^ (DEXA) Subscapular (SS) Skinfold Triceps Skinfold WHR Trunk Fat: Leg Fat (DEXA) SS: Triceps Ratio
Ko(61) | 73% Female 51.5 years Race NR | 5153 community volunteers for a primary care health check in Hong Kong in 1996–7 | BMI | Very High BF > 40% (female) > 30% (male) by Bl^†^ | Fair
Logue (35) | 67% Female ≥ 60 years In the larger (age ≥ 45) sample: 22% Black 75% White | Consecutive age-eligible outpatients (n=225 over the age of 60) seen in 1993 at 2 community-hospital-based, medical school-affiliated family practice centers in Ohio. | Elevated BMI >27.8 kg. (men) >27.3 kg. (women) Elevated WHR >0.95 (men) >0.80 (women) | None | Fair
Molarius (62) | % Female NR ≥ 55 years Race NR | Population sample (73%) of all people at least 55 years of age in Ommoord Sweden: 6423 participants | Elevated WC ≥102 cm (men) ≥ 88 cm (women) | BMI ≥ 30 OR elevated WHR Definition of Elevated WHR ≥0.95 (men) ≥0.80 (women) | Fair
Okosun (63) | Older Subset: 60–90 years (correlations reflect this group) General Sample: 53% Female; 42% White, 29% Black, 29% Hispanic | US NHANES III participants (sample size NR by age) | WC | BMI ≥ 30 | Fair
Olson (64) | 100% Female 55–69 Years (mean not reported) Race NR | Iowa Women's health study participants (n=38006) initially age 55–69 years in 1986, who were cancer-free (except skin cancer) at baseline | WHR WC BMI | None | Fair

Citation | Subset | Sens. | Spec | Correlations or Other Analyses
Deurenberg (59) | | NR | NR | Correlation: BMI& BF% [underlined: Age 56–65] MEN WOMEN [underlined: Age > 66] MEN WOMEN | 0.72 0.50 0.37 0.51 | p<0.01 p<0.01 NS NS | BF% measured by densitometry
Folsom (10) | | NR | NR | BMI WHR | WC 0.82 0.72 | WHR 0.4 | Pearson product moment correlation
Goodman-Gruen (60) | NR | NR | NR | Correlation with BF% (DEXA) (Age Adjusted) MEN WOMEN | BMI 0.73 0.80 | BF % (BI) 0.76 0.78 | WC 0.78 0.64 | WHR 0.22 0.16 | SS Skinfold 0.55 0.59 | Triceps Skinfold 0.57 0.67 | Trunk :Leg 0.57 0.65 | Trunk :Leg −0.3 0.13
Ko (61) Age 60–69 Age ≥70 Age 60–69 Age ≥ 70 | WOMEN BMI 26.2 BMI 25.5 MEN BMI 25.9 BMI 24.1 | 0.91 0.97 0.81 1 | 0.86 0.86 0.83 0.67 | NR
Logue (35) | NR | NR | NR | NR | Linear decrease in elevated BMI frequency seen with age (p<0.001 for men, p=0.05 in women). In women: Linear increase in central obesity (by WHR) with age (p=0.003), but not men. In men: elevated BMI dropped from just over 60% at age 60–69 to approximately 12% at age > 80, while elevated WHR fell from about 55% to 30%. In women: Elevated BMI dropped from approximately 60% at age 60–69 to about 25% at age > 80. Elevated WHR rose over the same timeframe: from about 80% to about 90%.
Molarius (62) | MEN Age 55–67 Age ≥ 70 WOMEN Age 55–67 Age ≥ 70 | 33.4 37.9 55.3 63.7 | 97.6 96.9 98 99.6 | MEN Age 55–69 Age ≥ 70 WOMEN Age 55–69 Age ≥ 70 | BMI WC BMI WC BMI WC BMI WC | WC 0.77 0.8 WC 0.75 0.73 | WHR 0.45 0.76 0.55 0.75 WHR 0.32 0.76 0.26 0.73 | (Pearson correlation coefficients)
Okosun (63) | NR | NR | NR | NR | ROC curves were use to determine the gender- and ethnic-specific WC cut-point corresponding to a BMI of ≥ 30. Among men and women, the derived WC value did not differ appreciably by race/ethnicity (103–105 in men, 100–101 in women). Larger WC correlated with lower BMI in older people
Olson (64) | | | | WHR WC | BMI 0.4 0.83 | WHR 0.72 | (Pearson correlation coefficients)

* WHR = Waist: Hip Ratio

† WC = Waist Circumference

‡ BI = Bioelectrical Impedence

§ BF = Body Fat

Three studies compared BMI to a referent measure: body fat percentage as measured by bioelectrical impedance, [60, 61] or by dual-energy X-Ray absorbtiometry (DEXA). [59] [60, 61] Correlation with body fat percentage was somewhat lower than in the general population, with most data falling within the range of 0.59 to 0.73 in men, and 0.50 to 0.80 in women. In a small sample of older (> 66 years) individuals, a low correlation (0.37) was noted in men. [59] This finding is difficult to interpret, as it is discordant with that of a much larger (n=385) study with mean age of 80 years. [60, 61] An Asian (Hong Kong) study found that relatively low BMI corresponded with very high body fat (>40% in women, and >30% in men); this finding, which became more pronounced with increasing age, likely reflects ethnic differences in fat accumulation. [61] In that study, from age 60–69, a BMI of 26 (mildly overweight) had a sensitivity of 91% in women, and 81% in men, with specificity of 86% and 83% respectively.

One study compared multiple adiposity measures to a referent measure of body fat percentage. [60] In men, among the common clinical diagnostic measures, body fat percentage (measured by DEXA) correlated highest with WC (0.78), followed by BMI (0.73), triceps (0.57), subscapularis (0.55) skin folds, and WHR (0.22). These correlations were minimally influenced by examining ratios between different skin fold measures, and generally slightly lower using bioelectrical impedance estimates of body fat percent. In women, BMI correlated most closely with body fat percentage (0.80), while triceps skin folds (0.67) and WC (0.64) showed similar, somewhat lower, correlations. Again, WHR did not correspond closely (0.16) to body fat percentage.

Of note, this study also measured the correlation between its two referent measures of body fat percentage (bioelectrical impedance versus DEXA – other data suggest DEXA is preferred in the elderly [65]). Correlation coefficients were 0.76 in men and 0.78 in women.

#### Comparison of diagnostic tests with each other

In five studies comparing BMI, WHR, and WC, [10, 35] [62] [63] [64]) pairwise comparisons typically showed the highest correlations between BMI and WC (0.73 to 0.83) [10, 62, 64], while the WC-WHR correlation was generally only slightly lower (0.72–0.76), [10] [62] [64] (although identical in one female sample). [62] WHR and BMI were weakly associated (0.26–0.55). In one study, age (55–69 versus ≥ 70 years) did not have an important effect on the relationship between these adiposity measures in either sex. [62]. However, the relative frequency of central adiposity (by WHR) increased with aging in one elderly cohort, while general adiposity (by BMI) dropped. [35]

One Swedish study evaluated the utility of WC to identify both generalized and central obesity in the aged. They found that an elevated waist circumference (≥ 102 cm. in men, ≥ 88 cm. in women) was very specific (specificity 96.9 – 99.6, depending on gender and age) for identifying people who were either obese by BMI (BMI ≥ 30) or had an elevated WHR (men: ≥ 0.95; women: ≥ 0.80) [62] although, particularly among men, this measure showed poor sensitivity (sensitivity 33.4 to 63.7).

Another nationwide US study examined data on men and women age 60–90 years using ROC curves to determine gender-and ethnic-specific WC cut-points corresponding the a BMI of 30 kg./m^2^. [63] Their derived WC values(103–105 cm. in men, 100–101 cm. in women) did not differ appreciably by race or ethnicity.

### III.A.3 Consistency of health outcomes associated with adiposity diagnosed using different measures (BMI, WC, or WHR)

We reviewed 23 longitudinal studies with at least 10 years of follow-up, which examined long-term morbidity or mortality in relationship to baseline adiposity (by BMI, WC, or WHR) (Table 4). Studies addressed both mortality and morbidity risk. Internal validity was fair to good. In general, patterns of absolute (generally unadjusted) and relative (typically adjusted for smoking and sometimes other potential confounders) risk were very similar in these studies. Most studies (18 out of 21) adjusted relative risk estimates for tobacco or included only nonsmokers. [10] [66, 67] [68–70] [47, 71–76] [9, 64, 77, 78] [79] [80] Some studies adjusted for direct mediators of obesity (diet and/or exercise), [80] [10, 64, 69, 76] thus have the potential to underestimate obesity’s net health effect. Studies typically did not exclude participants with early adverse health outcomes (e.g., ones in which baseline body weight may reflect an ongoing disease that subsequently leads to an event), however, consideration of studies with at least 10 years of follow-up should minimize this concern.

Table 4 Description of longitudinal studies examining the relationships between different measures of body weight and health risk

Included studies have at least 10 years of follow-up, with a mean baseline age of at least 60 years.

Author | Sample | Duration | Race | % Female | Baseline Age | Baseline BMI | % Never smoked | % Loss to f/u | Potential Confounders, Diet, Activity | Outcome
Abbot (66) | 1163 Non-smoking men with baseline age 55–68, of the Honolulu Heart Program, without high baseline CVA risk (hypertension, DM, LVH, CAD, CVA) | 22 years | Japanese Americans | 0 | 59.8 | NR | 100 | >99% mortality, very high morbidity | Nonsmokers RR^‡^ not adjusted for diet or PA^†^ | 1st thromboembolic stroke
Baik (67) | Subset of the Health Professionals Follow-up Study: male health professionals followed since 1986, without recent significant weight loss at baseline | 10 yr. | NR | 0 | ≥ 65 (no mean given) | NR | 44–54% in the larger group (varied with BMI) | NR | RR adjusted for smoking, age, FH MI or colon CA, profession, marital status, height, alcohol, vitamin and fiber intake | Mortality (Total and Specific)
Calle (68) | Generally healthy adults with no history of smoking, a subset (n not reported) of 1046154 participants with a broader age range, in the Cancer Prevention Study II. | 14 years | NR | 56% (larger cohort, not age specific) | ≥ 65 subset | NR by age | NR by age | 0.20% | Nonsmokers RR adjusted for age, education, physical activity, alcohol, marriage, aspirin or estrogen use, fat or vegetable consumption | Total Mortality
Cerhan (69) | Iowa 65+ Rural Health Study: 80% of the non-institutionalized residents at least 65 y/o in 2 Iowa counties: 81 % completed baseline data and had no history of prior prostate cancer | 10 yr. | NR | 0 | 73.5 | 26 | 42 | NR | RR adjusted for age, smoking, physical activity | Prostate Cancer Incidence
Cerhan (84) | 37932 Iowa women, randomly selected from those with drivers' licenses, and no cancer at baseline. Self-reported height, weight, and waist circumference. | 13 years | "Caucasian population" | 100 | 55–69 | NR | NR | NR | RR not adjusted for smoking, diet, activity | Non-Hodgkin's Lymphoma Incidence
Cornoni-Huntley (70) | NHEFS(f/u of HNANES I)-non-institutionalized civilian US Population | 10 years | 3339 total, 17% Black | 52% | 65–74 (mean NR) | NR | NR | NR | RR adjusted for Age and Smoking | Mortality
Dey (71) | 2287 men and women measured between 1971 & 1981 in Goteborg, Sweden, with no prior stroke | 15 years | NR | 54 | 70 | 26 | NR | 19% | RR adjusted for adjusted for cohort, height, smoking, lipids, diabetes, heart disease, blood pressure. | 1st stroke
Dey et al (72) | 2628 participants with BMI <40 and no cancer at baseline, recruited via 3 random community samples, examined in at age 70 between 1971–1981 in Gothenburg Sweden | 15 years | NR | 53% | 70 | 25.7 (Men) 26.0 (Women) | 22% Male 79%Female | NR | Spline analysis for trend adjusted for smoking. | Mortality
Dorn (73) | 190 Residents of Buffalo NY, a subset of the Buffalo Blood Pressure Study, randomly selected from the general population | 29 year | 100% White | 0 | 65–96: Mean 71 | Men: 25.3 Women: 26.3 | NR age-specific | NR | RR adjusted for age, education, smoking | All Cause and Cause-specific Mortality
Ellekjaer (74) | 6392 Norwegian men and women initially free from stroke, heart disease, diabetes, and without BP medication use. | 10 years | NR | 51 | 77 | Men: 24–25 (varied by age) Women: 25–27 | current smokers: men: 15–33%, women 2–12% (decreased with age) | Very low - used national death registry | RR adjusted for age, blood pressure, smoking | Total and Cause-Specific Mortality
Fitzgerald (75) | Subset of 18403 male civil servants in London (the Whitehall Study): 2387 men age 60–64 years between 1968–1970 | 15 years | NR | 0% | 60–64 | NR | 15.70% | NR | RR not adjusted for smoking, diet, or exercise | CHD Mortality
Folsom (10) | Iowa Women's Health Study Subset: post-menopausal women with no history of CA, CHD or diabetes, and full BMI, WHR data (31,702=n) | 11–12 years | 99% White | 100% | 55–69 | NR | 55–72 (differs by BMI) | NR | Overall RR adjusted for: Age, education, physical activity, alcohol, smoking, first birth,, estrogen use, vitamin use, diet, hypertension | All Cause & Specific Mortality, multiple measures of morbidity incidence
Harris (47) | 1581 participants of the Epidemiologic Follow-up Study of NHANES I, who provided a baseline BMI in 1971–1975, and were free of heart disease in 1982–1984. | From 1971–1975 to mid 1980's. | White | 61 | 60–76 in 1972–1974 | NR | 60% | NR | RR adjusted for age and smoking | CHD Event
Heitmann (76) | 787 men from a community sample in Gothenburg, Sweden | 22 years | NR | 0 | 60 | 25.5 | 21 | NR | RR adjusted for smoking and physical activity | Mortality
Launer (9) | NHEFS subset: 426 white women age 60–74 at the NHANES I sample, who did not report any disability in 1982–1984: looked for development of disability by 1986–1987 | Approximately 10 years | White | 100 | 66.1 | 26.4 | 79 | NR | RR adjusted for age, smoking, education, time to follow-up | Mobility disability
Mazza (77) | 1028 elderly subjects from a rural, low-income Italian populations in the "Cardiovascular Study in the Elderly" | 12 years | NR | 59% | 74.3 | 27.3 | NR | NR | Relative Risk adjusted for age, gender, smoking, resp. symptoms, ALT, ALP, town | Cancer mortality
Meyer (83) | Men and women age 50–89 at in a national tuberculosis screening exam in Norway (1963–1975). Data was available for 673,848 people: population attendance at initial screening was 80% age 50–69, 70% age 70–79, 42% for age 80 or over | mean 16.4 years | NR | 53% | 50–89 (mean NR) | NR | NR | NR | RR not adjusted for smoking | Fatal Hip Fracture
Olson (64) | Iowa Women's health study participants initially age 55–69 years in 1986, who were cancer-free (except skin cancer) at baseline (n=38,006) | 12 years | NR | 100% | 55–69 years (mean not noted) | NR | NR | NR | Relative Risk adjusted for age, smoking, physical activity, education, beer consumption | Lung Cancer
Shinton (82) | Subset of the Whitehall Study of 18403 male civil servants examined between 1967–1969 until 1985 | 15 years | NR | 0 | 55–64 (no mean reported) | NR | 19% (larger group) | NR | RR not adjusted for smoking, though sub-analyses showed smokers risk was ≥ 2-fold that of lean non-smokers for. | Stroke Mortality
Singh and Lindsted (78) | 12576 non-Hispanic white California Seventh-Day Adventist women who had never smoked | 26 years | White | 100% | 55–74 (no mean noted) | NR | 100 | 6% in a subset | Nonsmokers. RR is adjusted forage. | Cause-Specific Mortality
Singh (79) | Subset of the Adventist Health Study, non-Hispanic white adults in California | 12 years | White | 65% | 55–84 (no mean reported) | 13.4–65.6 Range | 100% | 3–4% per subsample | Never smokers | All Cause Mortality
Stevens (80) | A subset (n=46954) of participants in the Cancer Prevention Study I who had not history of smoking, were generally healthy, and without recent unintentional weight loss at enrollment. | 12 years | 100% White | 79% | ≥65 | Men: 23.2–25.1 Women: 23.4–25.0 | 100% | NR | Nonsmokers RR adjusted for age, education, physical activity, alcohol. | Total and Coronary Heart Disease Mortality
Takala (88) | 721 (80% of the total aged population) participants over the age of 65, initially sampled in coordination with tuberculosis screening in rural Hankasalmi Finland in 1971 | 10 years | NR | 57% | 71.6 | 27.3 | NR | NR | RR not adjusted for smoking, diet, exercise | Mortality

* NR: Not reported;

† PA: Physical Activity;

‡ RR: Relative Risk

Two different methods typically assessed statistical significance of the relationship between long-term health risk and baseline adiposity: (1) comparison of risk in different body size categories with risk in a “referent” range, and (2) assessment for a trend in risk across the range of baseline body size. Notably, when comparing risk across body size categories, many studies used the sample’s lowest values as referent. In a U-shaped relationship, with elevated risk for both the obese and the underweight, this technique limits ability to assess obesity risk, as it reflects risk of obesity versus underweight, rather than obesity versus “normal” weight.

#### III.A.3.i Mortality risk and different measures of obesity

[underlined: All Cause Mortality in Men:] The relationship between anthropometric adiposity measures and long-term all-cause mortality was best described for BMI. Point estimates of mortality followed a U-shaped pattern with increasing BMI (higher mortality at both extremes of body weight) (Table 5). Longitudinal data consistently showed minimal long-term all-cause mortality among those in the normal-to-overweight BMI range. Overall, the strength of association between BMI and mortality lessened with age; the same has been seen in a review incorporating studies of shorter duration. [81] Five of eight studies finding a U-shaped relationship between relative risk for all-cause mortality and BMI [67, 68, 70] [72] [73] [74] [76] [80] compared risk between the heaviest participants and those with a middle-range BMI. [68] [80] [76] [70] [72] In one, relative risk was 2.75 (CI 2.17 to 3.49) for a BMI of ≥ 35 kg./m^2^ versus 23.5 to 24.9 kg./m^2^ among men age 65 to 74, but only 1.53 (CI 1.15 to 2.04) for the same body size comparison among men aged 75 or above. [68] In another, adjusted for multiple confounders, the risk associated with higher BMI dampened with age, and was not statistically significant by the age of 85 years (75 years in women). [80] The study with the youngest sample (mean age of 60 at baseline) found significantly increased mortality risk with obesity: relative risk 1.5 (CI 1.09–1.86) for a BMI of > 30.2 kg./m^2^ versus 23.8 to 25.4 kg./m^2^. [76] Two with older baseline groups, (one with a range of 65–74 years [70] and the other with an average age of 70 years [72]) did not. Three studies comparing risk between the “tails” of the U-curve (e.g., heaviest versus thinnest participants), found no difference. [67] [73] [74] Only one [72] of three studies [67] [72] [74] assessing for trend across the baseline BMI range noted a significant effect.

Table 5 Summary of studies examining relationships between a) BMI b) Waist Circumference and c) Waist to Hip Ratio and prospective mortality risk

Reference | Baseline BMI | Incidence | 95% CI | p (Incid) | Relative Risk | 95% CI | p (trend: RR)
A. Studies Examining BMI and Mortality
Total Mortality
Baik (67) | <23 | NR | | NR | 1 | | .59 (trend)
Baik (67) | 23–24.9 | NR | | | 0.69 | .48–0.99 | .59 (trend)
Baik (67) | 25–26.9 | NR | | | 0.75 | .53–1.08 | .59 (trend)
Baik (67) | 27–29.9 | NR | | | 0.83 | .56–1.23 | .59 (trend)
Baik (67) | ≥ 30 | NR | | | 0.85 | .49–1.46 | .59 (trend)
Calle (68) | MEN
Calle (68) | Age 65–74 | Deaths / 100,000 py | | | Multivar RR | 95% CI | NR
Calle (68) | <20.5 | 1089 | NR | NR | 1.21 | 0.95–1.53 | NR
Calle (68) | 20.5–21.9 | 816 | NR | | 0.9 | 0.74–1.08 | NR
Calle (68) | 22.0–23.4 | 854 | NR | | 0.96 | 0.84–1.09 | NR
Calle (68) | 23.5–24.9 | 898 | NR | | 1 | | NR
Calle (68) | 25.0–26.4 | 941 | NR | | 1.04 | 0.93–1.16 | NR
Calle (68) | 26.5–27.9 | 1038 | NR | | 1.12 | 1.00–1.26 | NR
Calle (68) | 28.0–29.9 | 1270 | NR | | 1.34 | 1.19–1.52 | NR
Calle (68) | 30.0–31.9 | 1370 | NR | | 1.42 | 1.22–1.66 | NR
Calle (68) | 32.0–34.9 | 1798 | NR | | 1.85 | 1.54–2.22 | NR
Calle (68) | ≥ 35 | 2767 | NR | | 2.75 | 2.17–3.49 | NR
Calle (68) | AGE ≥ 75
Calle (68) | <20.5 | 4564 | NR | NR | 1.16 | 1.02–1.32 | NR
Calle (68) | 20.5–21.9 | 4344 | NR | | 1.12 | 1.01–1.24 | NR
Calle (68) | 22.0–23.4 | 3956 | NR | | 1.01 | 0.93–1.09 | NR
Calle (68) | 23.5–24.9 | 3924 | NR | | 1 | | NR
Calle (68) | 25.0–26.4 | 4024 | NR | | 1.01 | 0.94–1.09 | NR
Calle (68) | 26.5–27.9 | 4206 | NR | | 1.06 | 0.97–1.15 | NR
Calle (68) | 28.0–29.9 | 4840 | NR | | 1.21 | 1.10–1.33 | NR
Calle (68) | 30.0–31.9 | 4687 | NR | | 1.16 | 1.01–1.32 | NR
Calle (68) | 32.0–34.9 | 5393 | NR | | 1.31 | 1.10–1.55 | NR
Calle (68) | > 35 | 6154 | NR | | 1.53 | 1.15–2.04 | NR
Calle (68) | WOMEN
Calle (68) | Age 65–74
Calle (68) | <18.5 | 594 | NR | NR | 0.99 | 0.78–1.25 | NR
Calle (68) | 18.5–20.4 | 531 | NR | | 0.91 | 0.80–1.03 | NR
Calle (68) | 20.5–21.9 | 503 | NR | | 0.86 | 0.77–0.96 | NR
Calle (68) | 22.0–23.4 | 498 | NR | | 0.84 | 0.76–0.93 | NR
Calle (68) | 23.5–24.9 | 595 | NR | | 1 | | NR
Calle (68) | 25.0–26.4 | 598 | NR | | 0.99 | 0.89–1.10 | NR
Calle (68) | 26.5–27.9 | 636 | NR | | 1.04 | 0.94–1.16 | NR
Calle (68) | 28.0–29.9 | 796 | NR | | 1.28 | 1.15–1.43 | NR
Calle (68) | 30.0–31.9 | 836 | NR | | 1.32 | 1.17–1.50 | NR
Calle (68) | 32.0–34.9 | 1111 | NR | | 1.71 | 1.51–1.95 | NR
Calle (68) | 35.0–39.9 | 1299 | NR | | 1.99 | 1.69–2.34 | NR
Calle (68) | ≥ 40 | 1434 | NR | | 2.09 | 1.57–2.78 | NR
Calle (68) | AGE ≥ 75
Calle (68) | <18.5 | 4051 | NR | NR | 1.44 | 1.31–1.58 | NR
Calle (68) | 18.5–20.4 | 3124 | NR | | 1.16 | 1.09–1.25 | NR
Calle (68) | 20.5–21.9 | 2848 | NR | | 1.06 | 1.00–1.13 | NR
Calle (68) | 22.0–23.4 | 2732 | NR | | 1.01 | 0.96–1.08 | NR
Calle (68) | 23.5–24.9 | 2711 | NR | | 1 | | NR
Calle (68) | 25.0–26.4 | 2837 | NR | | 1.04 | 1.97–1.10 | NR
Calle (68) | 26.5–27.9 | 2960 | NR | | 1.07 | 1.00–1.15 | NR
Calle (68) | 28.0–29.9 | 3209 | NR | | 1.15 | 1.07–1.23 | NR
Calle (68) | 30.0–31.9 | 3514 | NR | | 1.25 | 1.15–1.35 | NR
Calle (68) | 32.0–34.9 | 3939 | NR | | 1.36 | 1.23–1.49 | NR
Calle (68) | 35.0–39.9 | 4348 | NR | | 1.53 | 1.33–1.75 | NR
Calle (68) | ≥ 40 | 4363 | NR | | 1.41 | 1.10–1.81 | NR
Cornoni-Huntley (70) | BLACK MEN
Cornoni-Huntley (70) | <20.5 | U-shaped graph | | NR | 2.3 | 1.4–3.9 | NR
Cornoni-Huntley (70) | 20.5–22.95 | | | | 1.8 | 1.1–2.8 | NR
Cornoni-Huntley (70) | 22.95–25.58 | | | | 1 | | NR
Cornoni-Huntley (70) | 25.58–29.55 | | | | 1.2 | 0.8–1.9 | NR
Cornoni-Huntley (70) | ≥ 29.55 | | | | 1.4 | 0.8–2.4 | NR
Cornoni-Huntley (70) | BLACK WOMEN
Cornoni-Huntley (70) | < 22.18 | U-shaped graph | | NR | 1.9 | 1.1–3.3 | NR
Cornoni-Huntley (70) | 22.18–26.22 | | | | 1.3 | 0.8–2.2 | NR
Cornoni-Huntley (70) | 26.22–28.82 | | | | 1 | | NR
Cornoni-Huntley (70) | 28.82–34.37 | | | | 0.9 | 0.5–1.6 | NR
Cornoni-Huntley (70) | ≥34.37 | | | | 1.3 | 0.7–2.3 | NR
Cornoni-Huntley (70) | WHITE MEN
Cornoni-Huntley (70) | <21.68 | U-shaped graph | | NR | 1.3 | 1–1.6 | NR
Cornoni-Huntley (70) | 21.68–24.42 | | | | 1.2 | 0.9–1.4 | NR
Cornoni-Huntley (70) | 24.42–26.39 | | | | 1 | | NR
Cornoni-Huntley (70) | 26.39–29.3 | | | | 1 | 0.8–1.2 | NR
Cornoni-Huntley (70) | ≥ 29.30 | | | | 1.1 | 0.9–1.4 | NR
Cornoni-Huntley (70) | WHITE WOMEN
Cornoni-Huntley (70) | <21.43 | U-shaped graph | | NR | 1.7 | 1.3–2.2 | NR
Cornoni-Huntley (70) | 21.43–24.37 | | | | 1.2 | 0.9–1.6 | NR
Cornoni-Huntley (70) | 24.37–26.95 | | | | 1 | | NR
Cornoni-Huntley (70) | 26.95–31.26 | | | | 1.4 | 1.1–1.8 | NR
Cornoni-Huntley (70) | ≥ 31.26 | | | | 1.6 | 1.2–2.1 | NR
Dey (72) | MEN
Dey (72) | 14.0–22.6 | NR | | NR | 1.2 | 0.96–1.51 | 0.000 (nonlinear)
Dey (72) | 22.7–24.6 | NR | | | 1.07 | 0.85–1.34 | 0.000 (nonlinear)
Dey (72) | 24.7–26.4 | NR | | | 1 | ref | 0.000 (nonlinear)
Dey (72) | 26.5–28.5 | NR | | | 1.01 | 0.81–1.26 | 0.000 (nonlinear)
Dey (72) | 28.6–39.2 | NR | | | 1.19 | 0.95–1.49 | 0.000 (nonlinear)
Dey (72) | WOMEN
Dey (72) | 14.1–22.5 | NR | | NR | 1.49 | 1.14–1.96 | 0.004 (nonlinear)
Dey (72) | 22.6–24.5 | NR | | | 1.16 | 0.88–1.53 | 0.004 (nonlinear)
Dey (72) | 24.6–26.5 | NR | | | 1 | | 0.004 (nonlinear)
Dey (72) | 26.6–29.2 | NR | | | 1.16 | 0.88–1.52 | 0.004 (nonlinear)
Dey (72) | 29.3–39.8 | NR | | | 1.25 | 0.95–1.64 | 0.004 (nonlinear)
Dorn (73) | 17.9–22.9 | NR | | NR | 1
Dorn (73) | 23.0–25.1 | NR | | | 0.67 | | NS (Graph)
Dorn (73) | 25.2–27.4 | NR | | | 0.63 | | NS (Graph)
Dorn (73) | 27.5–47.0 | NR | | | 0.77 | | NS (Graph)
Ellekjaer (74) | MEN
Ellekjaer (74) | ≤ 22.95 | 9.09 | NR | NR | 1 | | 0.11
Ellekjaer (74) | 22.96–25.10 | 6.68 | NR | | 0.8 | .69–.93 | 0.11
Ellekjaer (74) | 25.11–27.35 | 6.69 | NR | | 0.8 | .69–.93 | 0.11
Ellekjaer (74) | 27.36 | 6.61 | NR | | 0.88 | .75–1.02 | 0.11
Ellekjaer (74) | WOMEN
Ellekjaer (74) | ≤ 23.23 | 6.46 | NR | | 1 | | <0.01
Ellekjaer (74) | 23.24–25.97 | 4.54 | NR | | 0.74 | .62–.88 | <0.01
Ellekjaer (74) | 25.98–29.00 | 3.97 | NR | | 0.62 | .52–.75 | <0.01
Ellekjaer (74) | ≥ 29.01 | 4.13 | NR | | 0.68 | .57–.81 | <0.01
Folsom (10) | | Cases/100py
Folsom (10) | < 22.8 | 0.88 | NR | NR | 1 | | 0.05 Multivariable RR for Quintile 5 vs. 1: 0.91(0.8–1.9)
Folsom (10) | 22.80– 24.87 | 0.70 | NR | | 0.76 | 0.7–0.9 | 0.05 Multivariable RR for Quintile 5 vs. 1: 0.91(0.8–1.9)
Folsom (10) | 24.87–27.06 | 0.66 | NR | | 0.74 | 0.7–0.8 | 0.05 Multivariable RR for Quintile 5 vs. 1: 0.91(0.8–1.9)
Folsom (10) | 27.06–30.21 | 0.64 | NR | | 0.71 | 0.6–0.8 | 0.05 Multivariable RR for Quintile 5 vs. 1: 0.91(0.8–1.9)
Folsom (10) | >30.21 | 0.82 | NR | | 0.91 | 0.8–1.0 | 0.05 Multivariable RR for Quintile 5 vs. 1: 0.91(0.8–1.9)
Heitmann (76) | 21.3 | NR | | NR | 1.3 | 0.94–1.68 | NR
Heitmann (76) | 23.8 | NR | | | 1.1 | NR | NR
Heitmann (76) | 25.4 | NR | | | 1 | | NR
Heitmann (76) | 27.1 | NR | | | 1.2 | NR | NR
Heitmann (76) | 30.2 | NR | | | 1.5 | 1.09–1.96 | NR
Singh (79) | WOMEN
Singh (79) | 13.4–20.6 | NR | | NR | 1.3 | 1.1–1.6 | <0.00001 (nonlinear)
Singh (79) | 20.7–22.4 | NR | | | 0.9 | 0.7–1.2 | <0.00001 (nonlinear)
Singh (79) | 22.5–24.2 | NR | | | 1 | | <0.00001 (nonlinear)
Singh (79) | 24.3–27.4 | NR | | | 1.1 | 0.9–1.3 | <0.00001 (nonlinear)
Singh (79) | 27.5–65.6 | NR | | | 1.5 | 1.2–1.8 | <0.00001 (nonlinear)
Singh (79) | MEN
Singh (79) | 13.5–22.3 | NR | | NR | 1.3 | 1.0–1.9 | 0.009
Singh (79) | 22.4–23.7 | NR | | | 1.5 | 1.1–2.0 | 0.009
Singh (79) | 23.7–25.3 | NR | | | 1 | | 0.009
Singh (79) | 25.4–27.3 | NR | | | 1.2 | 0.9–1.7 | 0.009
Singh (79) | 27.4–40.5 | NR | | | 1.8 | 1.3–2.5 | 0.009
Stevens (80) | MEN | Deaths per 100,000 person-years
Stevens (80) | Men age 65–74 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Men age 75–84 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Men age ≥ 85 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | WOMEN
Stevens (80) | Women age 65–74 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Women age 75–84 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Women age > 85 | U-Shaped Curves | | NR | U-Curves | | NR
Takala (88) | All | % Survival
Takala (88) | <23 | 39.90 | NR | NR | NR | | NR
Takala (88) | 23–25 | 42.30 | NR | | NR | | NR
Takala (88) | 26–29 | 51.00 | NR | | NR | | NR
Takala (88) | ≥ 30 | 54.20 | NR | | NR | | NR
Takala (88) | MEN
Takala (88) | <23 | 39.00 | NR | NR | NR | | NR
Takala (88) | 23–25 | 38.60 | NR | | NR | | NR
Takala (88) | 26–29 | 40.90 | NR | | NR | | NR
Takala (88) | ≥ 30 | 48.70 | NR | | NR | | NR
Takala (88) | WOMEN
Takala (88) | <23 | 41.10 | NR | NR | NR | | NR
Takala (88) | 23–25 | 45.70 | NR | | NR | | NR
Takala (88) | 26–29 | 58.20 | NR | | NR | | NR
Takala (88) | ≥ 30 | 55.90 | NR | | NR | | NR
Disease-Specific Mortality
Baik (67) | Cancer Mortality
Baik (67) | 23 | NR | | NR | 1 | | 0.21
Baik (67) | 23–24.9 | NR | | | 0.87 | .48–1.6 | 0.21
Baik (67) | 25–26.9 | NR | | | 0.77 | .53–1.08 | 0.21
Baik (67) | 27–29.9 | NR | | | 0.64 | .31–1.34 | 0.21
Baik (67) | ≥ 30 | NR | | | 0.67 | .24–1.87 | 0.21
Baik (67) | CVD Mortality
Baik (67) | 23 | 11.00 | | NR | 1 | | 0.98
Baik (67) | 23–24.9 | 11.00 | | | 0.58 | .25–1.38 | 0.98
Baik (67) | 25–26.9 | NR | | | 0.95 | .43–2.11 | 0.98
Baik (67) | 27–29.9 | NR | | | 0.94 | .39–2.24 | 0.98
Baik (67) | ≥ 30 | NR | | | 0.7 | .19–2.66 | 0.98
Dorn (73) | Cardiovascular Mortality | NR
Dorn (73) | 17.9–22.9 | NR | | NR | 1 | NR
Dorn (73) | 23.0–25.1 | NR | | | 0.77 | NR | NS (Graph)
Dorn (73) | 25.2–27.4 | NR | | | 0.66 | NR | NS (Graph)
Dorn (73) | 27.5–47.0 | NR | | | 0.73 | NR | NS (Graph)
Dorn (73) | CHD Mortality
Dorn (73) | 17.9–22.9 | NR | | NR | 1 | NR
Dorn (73) | 23.0–25.1 | NR | | | 0.73 | NR | NS (Graph)
Dorn (73) | 25.2–27.4 | NR | | | 0.7 | NR | NS (Graph)
Dorn (73) | 27.5–47.0 | NR | | | 0.78 | NR | NS (Graph)
Ellekjaer (74) | | Cases/100 py
Ellekjaer (74) | Death from CVD: MEN
Ellekjaer (74) | ≤ 22.95 | 0.93 | NR | NR | 1 | | 0.71
Ellekjaer (74) | 22.96–25.10 | 0.96 | NR | | 1.1 | 0.72–1.67 | 0.71
Ellekjaer (74) | 25.11–27.35 | 0.71 | NR | | 0.74 | 0.46–1.18 | 0.71
Ellekjaer (74) | 27.36 | 1.02 | NR | | 1.21 | 0.79–1.84 | 0.71
Ellekjaer (74) | Death from CVD: Women
Ellekjaer (74) | ≤ 23.23 | 1.08 | NR | NR | 1 | | 0.16
Ellekjaer (74) | 23.24–25.97 | 0.72 | NR | | 0.85 | .55–1.32 | 0.16
Ellekjaer (74) | 25.98–29.00 | 0.66 | NR | | 0.69 | .43–1.10 | 0.16
Ellekjaer (74) | ≥ 29.01 | 0.63 | NR | | 0.76 | .48–1.19 | 0.16
Ellekjaer (74) | Death from CHD: Men
Ellekjaer (74) | ≤ 22.95 | 1.91 | NR | NR | 1 | | 0.76
Ellekjaer (74) | 22.96–25.10 | 1.39 | NR | | 0.8 | .58–1.11 | 0.76
Ellekjaer (74) | 25.11–27.35 | 1.62 | NR | | 0.98 | .71–1.34 | 0.76
Ellekjaer (74) | 27.36 | 1.56 | NR | | 0.99 | .71–1.36 | 0.76
Ellekjaer (74) | Death from CHD: Women
Ellekjaer (74) | ≤ 23.23 | 1.04 | NR | NR | 1 | | 0.35
Ellekjaer (74) | 23.24–25.97 | 0.84 | NR | | 0.97 | .65–1.45 | 0.35
Ellekjaer (74) | 25.98–29.00 | 1.07 | NR | | 0.99 | .67–1.48 | 0.35
Ellekjaer (74) | ≥ 29.01 | 0.80 | NR | | 0.81 | .86–2.52 | 0.35
Fitzgerald (75) | CHD Mortality | Cases/100 py
Fitzgerald (75) | <22.4 | 1.18 | 0.90–1.49 | 0.28 (linear) | NR | | NR
Fitzgerald (75) | 22.4–24.0 | 0.93 | 0.70–1.25 | 0.28 (linear) | NR | | NR
Fitzgerald (75) | 24.1–25.4 | 1.23 | 0.97–1.55 | 0.28 (linear) | NR | | NR
Fitzgerald (75) | 25.5–27.0 | 1.21 | 0.96–1.52 | 0.28 (linear) | NR | | NR
Fitzgerald (75) | >27.0 | 1.27 | 1.03–1.56 | 0.28 (linear) | NR | | NR
Folsom (10) | CHD Mortality
Folsom (10) | < 22.8 | 0.11 | NR | NR | 1 | | <0.001 Multivar RR 1.7 (1.2–2.3)
Folsom (10) | 22.80–24.87 | 0.11 | NR | | 0.94 | 0.7–1.3 | <0.001 Multivar RR 1.7 (1.2–2.3)
Folsom (10) | 24.87–27.06 | 0.13 | NR | | 1.1 | 0.8–1.6 | <0.001 Multivar RR 1.7 (1.2–2.3)
Folsom (10) | 27.06–30.21 | 0.12 | NR | | 1.1 | 0.8–1.5 | <0.001 Multivar RR 1.7 (1.2–2.3)
Folsom (10) | >30.21 | 0.18 | NR | | 1.6 | 1.2–2.2 | <0.001 Multivar RR 1.7 (1.2–2.3)
Folsom (10) | Other CVD Mortality
Folsom (10) | < 22.8 | 0.11 | NR | NR | 1 | | 0.7 Multivar RR 0.72 (0.5–1.1)
Folsom (10) | 22.80–24.87 | 0.09 | NR | | 0.77 | 0.6–1.1 | 0.7 Multivar RR 0.72 (0.5–1.1)
Folsom (10) | 24.87–27.06 | 0.07 | NR | | 0.60 | 0.4–0.9 | 0.7 Multivar RR 0.72 (0.5–1.1)
Folsom (10) | 27.06–30.21 | 0.10 | NR | | 0.86 | 0.6–1.2 | 0.7 Multivar RR 0.72 (0.5–1.1)
Folsom (10) | >30.21 | 0.10 | NR | | 0.89 | 0.6–1.2 | 0.7 Multivar RR 0.72 (0.5–1.1)
Folsom (10) | Cancer Mortality
Folsom (10) | < 22.8 | 0.40 | NR | NR | 1
Folsom (10) | 22.80–24.87 | 0.35 | NR | | 0.84 | 0.7–1.0 | 0.06 Multivar RR 1.0 (0.8–1.2)
Folsom (10) | 24.87–27.06 | 0.31 | NR | | 0.77 | 0.6–0.9 | 0.06 Multivar RR 1.0 (0.8–1.2)
Folsom (10) | 27.06–30.21 | 0.30 | NR | | 0.72 | 0.6–0.9 | 0.06 Multivar RR 1.0 (0.8–1.2)
Folsom (10) | >30.21 | 0.36 | NR | | 0.89 | 0.7–1.1 | 0.06 Multivar RR 1.0 (0.8–1.2)
Mazza (77) | Cancer Mortality
Mazza (77) | ≤ 22.7 | 0.14 | NR | 0.04 | 1.63 | .96–2.56 | NR
Mazza (77) | 22.8–25 | 0.08 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | 25.1–26.7 | 0.12 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | 26.8–29.5 | 0.11 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | ≥29.6 | 0.10 | NR | | 0.91 | 0.53–1.56 | NR
Mazza (77) | Lung Cancer Mortality
Mazza (77) | ≤ 22.7 | 0.05 | NR | <0.004 | 2 | 1.13–4.52 | NR
Mazza (77) | 22.8–25 | 0.05 | NR | | 1.24 | 0.98–1.46 | NR
Mazza (77) | 25.1–26.7 | 0.03 | NR | | 1 (largest 3 quintiles) | | NR
Mazza (77) | 26.8–29.5 | 0.03 | NR | | 1 (largest 3 quintiles) | | NR
Mazza (77) | >29.6 | 0.02 | NR | | 1 (largest 3 quintiles) | | NR
Mazza (77) | Liver Cancer Mortality
Mazza (77) | ≤ 22.7 | 0.03 | NR | <0.02 | 2.69 | 1.04–5.6 | NR
Mazza (77) | 22.8–25 | 0.03 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | 25.1–26.7 | 0.03 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | 26.8–29.5 | 0.02 | NR | | 1 (middle 3 quintiles) | | NR
Mazza (77) | ≥29.6 | 0.01 | NR | | 0.88 | 0.32–1.21 | NR
Meyer (83) | Fatal Hip Fracture: Women
Meyer (83) | AGE 60–69
Meyer (83) | <24.3 | 8.34 | NR | NR | 1 | | NR
Meyer (83) | 24.3 – 27.0 | 7.09 | NR | | 0.82 | 0.72–0.95 | NR
Meyer (83) | 27.1–30 | 6.33 | NR | | 0.73 | 0.62–0.84 | NR
Meyer (83) | >30 | 6.81 | NR | | 0.82 | 0.72–0.95 | NR
Meyer (83) | AGE 70–79
Meyer (83) | < 24.1 | 34.03 | NR | NR | 1 | | NR
Meyer (83) | 24.1–26.9 | 22.61 | NR | | 0.65 | 0.57–0.73 | NR
Meyer (83) | 27–29.9 | 20.36 | NR | | 0.59 | 0.52–0.67 | NR
Meyer (83) | >29.9 | 18.64 | NR | | 0.57 | 0.50–0.65 | NR
Meyer (83) | AGE 80–89
Meyer (83) | < 23.1 | 70.84 | NR | NR | 1 | | NR
Meyer (83) | 23.1 – 25.9 | 52.76 | NR | | 0.73 | 0.56–0.94 | NR
Meyer (83) | 2.6–28.9 | 44.64 | NR | | 0.59 | 0.45–0.78 | NR
Meyer (83) | >28.9 | 38.87 | NR | | 0.55 | 0.41–0.73 | NR
Meyer (83) | Fatal Hip Fracture: Men
Meyer (83) | AGE 60–69
Meyer (83) | <23.1 | 7.47 | NR | NR | 1 | | NR
Meyer (83) | 23.1–25.2 | 5.10 | NR | | 0.66 | 0.56–0.80 | NR
Meyer (83) | 25.3–27.5 | 4.36 | NR | | 0.57 | 0.48–0.69 | NR
Meyer (83) | >27.5 | 3.73 | NR | | 0.52 | 0.42–0.64 | NR
Meyer (83) | AGE 70–79
Meyer (83) | <22.9 | 23.80 | NR | NR | 1 | | NR
Meyer (83) | 22.9–25.2 | 16.09 | NR | | 0.68 | 0.57–0.81 | NR
Meyer (83) | 25.3–27.5 | 11.59 | NR | | 0.48 | 0.39–0.58 | NR
Meyer (83) | >27.5 | 10.65 | NR | | 0.48 | 0.39–0.59 | NR
Meyer (83) | AGE 80–89
Meyer (83) | <22.4 | 49.12 | NR | NR | 1 | | NR
Meyer (83) | 22.4–24.6 | 29.41 | NR | | 0.58 | 0.40–0.85 | NR
Meyer (83) | 24.7–26.9 | 31.41 | NR | | 0.62 | 0.43–0.90 | NR
Meyer (83) | >26.9 | 23.50 | NR | | 0.52 | 0.340–.78 | NR
Shinton (82) | | # Stroke Deaths/100 Py
Shinton (82) | ≤22.4 | 0.163485 | NR | NR | 1 | | NR
Shinton (82) | 22.5–24.0 | 0.153561 | | | 0.97 | NR | NR
Shinton (82) | 24.1–25.4 | 0.136304 | | | 0.83 | NR | NR
Shinton (82) | 25.5–27.0 | 1.490826 | | | 0.91 | NR | NR
Shinton (82) | ≥ 27.1 | 0.194901 | | | 1.19 | 0.7–2.0 | NR
Singh (78) | Ischemic Heart Disease Death | 487 deaths
Singh (78) | <21.3 | NR | | | 0.9 | 0.7–1.2 | NR
Singh (78) | 21.4–27.4 | NR | | | 1 | | NR
Singh (78) | >27.4 | NR | | | 1.2 | 1.0–1.5 | NR
Singh (78) | CVD Mortality | 232 deaths
Singh (78) | <21.3 | NR | | | 0.8 | 0.5–1.2 | NR
Singh (78) | 21.4–27.4 | NR | | | 1.00 | | NR
Singh (78) | >27.4 | NR | | | 1.10 | 0.8–1.5 | NR
Singh (78) | Other Cardiovascular Mortality | 200 deaths
Singh (78) | <21.3 | NR | | | 0.9 | 0.6–1.4 | NR
Singh (78) | 21.4–27.4 | NR | | | 1 | | NR
Singh (78) | >27.4 | NR | | | 1.5 | 1.1–2.0 | NR
Singh (78) | Cancer Mortality | 188 deaths
Singh (78) | <21.3 | NR | | | 0.9 | 0.6–1.3 | NR
Singh (78) | 21.4–27.4 | NR | | | 1.00 | | NR
Singh (78) | >27.4 | NR | | | 1.00 | 0.7–1.4 | NR
Singh (78) | Other Mortality | 238 deaths
Singh (78) | <21.3 | NR | | | 0.9 | 0.6–1.3 | NR
Singh (78) | 21.4–27.4 | NR | | | 1 | | NR
Singh (78) | >27.4 | NR | | | 1 | 0.8–1.4 | NR
Stevens (80) | MEN | Cardiovascular Deaths per 100,000 p-y
Stevens (80) | Men age 65–74 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Men age 75–84 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Men age ≥ 85 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | WOMEN
Stevens (80) | Women age 65–74 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Women age 75–84 | U-Shaped Curves | | NR | U-Curves | | NR
Stevens (80) | Women age > 85 | U-Shaped Curves | | NR | U-Curves | | NR

B. Studies Examining Waist Circumference and Mortality
Total Mortality
Reference | BaselineWC | Incidence | 95% CI | p (incidence) | Relative Risk | 95% CI | p (RR)
Baik (67) | WC (inches) | Total Mortality
Baik (67) | <34.5 | NR | | NR | 1 | | 0.11
Baik (67) | 34.5–36.2 | NR | | NR | 0.97 | .70–1.33 | 0.11
Baik (67) | 36.3–37.9 | NR | | NR | 0.82 | .59–1.16 | 0.11
Baik (67) | 38.0–40.2 | NR | | NR | 0.97 | .72–1.32 | 0.11
Baik (67) | ≥ 40.3 | NR | | NR | 1.17 | .87–1.59 | 0.11
Folsom (10) | WC (cm) | Total Mortality
Folsom (10) | < 74.3 | 0.67 | NR | NR | 1 | | <0.001 Multivar RR 1.1 (1.0–1.3)
Folsom (10) | 74.3–80 | 0.71 | NR | NR | 0.99 | 0.9–1.1 | <0.001 Multivar RR 1.1 (1.0–1.3)
Folsom (10) | 80–87.3 | 0.66 | NR | NR | 0.90 | 0.8–1.0 | <0.001 Multivar RR 1.1 (1.0–1.3)
Folsom (10) | 87.3–96.3 | 0.71 | NR | NR | 0.93 | 0.8–1.1 | <0.001 Multivar RR 1.1 (1.0–1.3)
Folsom (10) | >96.3 | 0.96 | NR | NR | 1.3 | 1.1–1.5 | <0.001 Multivar RR 1.1 (1.0–1.3)
Disease-Specific Mortality
Baik (67) | WC (inches) | CVD Death
Baik (67) | <34.5 | NR | | NR | 1 | | <0.001
Baik (67) | 34.5–36.2 | NR | | | 0.72 | 0.27–1.96 | <0.001
Baik (67) | 36.3–37.9 | NR | | | 2.37 | 1.03–5.45 | <0.001
Baik (67) | 38.0–40.2 | NR | | | 1.98 | 0.88–4.48 | <0.001
Baik (67) | ≥ 40.3 | NR | | | 3.5 | 1.6–7.66 | <0.001
Baik (67) | WC (inches) | Cancer Death
Baik (67) | <34.5 | NR | | NR | 1 | | NR
Baik (67) | 34.5–36.2 | NR | | | 1.34 | .82–2.19 | NR
Baik (67) | 36.3–37.9 | NR | | | 0.75 | .43–1.32 | NR
Baik (67) | 38.0–40.2 | NR | | | 0.96 | 0.59–1.59 | NR
Baik (67) | ≥ 40.3 | NR | | | 0.93 | 0.56–1.55 | NR
Baik (67) | | Respiratory Disease Death
Baik (67) | Lowest tertile | NR | | NR | 1 | | 0.01
Baik (67) | 2nd tertile | NR | | | 0.59 | 0.27–1.29 | 0.01
Baik (67) | Largest Tertile | NR | | | 0.28 | 0.10–0.75 | 0.01
Folsom (10) | WC (cm) | CHD Mortality
Folsom (10) | < 74.3 | 0.07 | | NR | 1 | | <0.001 Multivar RR 2.2 (1.5–3.2)
Folsom (10) | 74.3–80 | 0.11 | | | 1.5 | 1.0–2.1 | <0.001 Multivar RR 2.2 (1.5–3.2)
Folsom (10) | 80–87.3 | 0.12 | | | 1.6 | 1.1–2.2 | <0.001 Multivar RR 2.2 (1.5–3.2)
Folsom (10) | 87.3–96.3 | 0.14 | | | 1.7 | 1.2–2.5 | <0.001 Multivar RR 2.2 (1.5–3.2)
Folsom (10) | >96.3 | 0.21 | | | 2.6 | 1.9–3.6 | <0.001 Multivar RR 2.2 (1.5–3.2)
Folsom (10) | WC (cm) | Other CVD Mortaltiy
Folsom (10) | < 74.3 | 0.07 | | NR | 1 | | 0.1 Multivar RR 1.2 (0.8–1.2)
Folsom (10) | 74.3–80 | 0.11 | | | 1.4 | .97–2 | 0.1 Multivar RR 1.2 (0.8–1.2)
Folsom (10) | 80–87.3 | 0.08 | | | 1 | .7–1.5 | 0.1 Multivar RR 1.2 (0.8–1.2)
Folsom (10) | 87.3–96.3 | 0.10 | | | 1.2 | .8–1.7 | 0.1 Multivar RR 1.2 (0.8–1.2)
Folsom (10) | >96.3 | 0.13 | | | 1.5 | 1.1–2.2 | 0.1 Multivar RR 1.2 (0.8–1.2)
Folsom (10) | WC (cm) | Cancer Mortality
Folsom (10) | < 74.3 | 0.33 | | NR | 1 | | 0.31 Multivar RR 1.2 (0.96–1.4)
Folsom (10) | 74.3–80 | 0.35 | | | 1 | 0.8–1.2 | 0.31 Multivar RR 1.2 (0.96–1.4)
Folsom (10) | 80–87.3 | 0.30 | | | 0.84 | 0.7–1.0 | 0.31 Multivar RR 1.2 (0.96–1.4)
Folsom (10) | 87.3–96.3 | 0.33 | | | 0.88 | 0.7–1.1 | 0.31 Multivar RR 1.2 (0.96–1.4)
Folsom (10) | >96.3 | 0.42 | | | 1.2 | 0.97–1.4 | 0.31 Multivar RR 1.2 (0.96–1.4)

C. Studies Examining Waist to Hip Ratio and Mortality
Total Mortality
Reference | Baseline WHR | Incidence | 95% CI | p (incidence) | Relative Risk | 95% CI | p (RR)
Baik (67) | WHR
Baik (67) | <0.9 | NR | | NR | 1 | | 0.1
Baik (67) | 0.9–0.91 | NR | | | 0.78 | .52–1.17 | 0.1
Baik (67) | 0.92–0.94 | NR | | | 0.85 | 0.62–1.18 | 0.1
Baik (67) | 0.95–0.97 | NR | | | 1.06 | 0.78–1.43 | 0.1
Baik (67) | > 0.98 | NR | | | 1.08 | 0.81–1.43 | 0.1
Folsom (10) | WHR
Folsom (10) | < 0.76 | 0.55 | NR | NR | 1 | | <0.001 Multivar RR 1.2 (1.1–1.4)
Folsom (10) | 0.76- 0.81 | 0.61 | NR | | 1.1 | 0.9–1.2 | <0.001 Multivar RR 1.2 (1.1–1.4)
Folsom (10) | 0.81–0.85 | 6.70 | NR | | 1.2 | 1.1–1.4 | <0.001 Multivar RR 1.2 (1.1–1.4)
Folsom (10) | 0.85–0.9 | 0.83 | NR | | 1.3 | 1.2–1.5 | <0.001 Multivar RR 1.2 (1.1–1.4)
Folsom (10) | >0.90 | 0.97 | NR | | 1.5 | 1.4–1.8 | <0.001 Multivar RR 1.2 (1.1–1.4)
Disease-Specific Mortality
Folsom (10) | WHR | CHD Mortality
Folsom (10) | < 0.76 | 0.07 | NR | NR | 1 | | <0.001 Multivar RR 1.9 (1.3–2.9)
Folsom (10) | 0.76–0.81 | 0.09 | NR | | 1.3 | | <0.001 Multivar RR 1.9 (1.3–2.9)
Folsom (10) | 0.81–0.85 | 0.09 | NR | | 1.6 | 0.9–1.9 | <0.001 Multivar RR 1.9 (1.3–2.9)
Folsom (10) | 0.85–0.9 | 0.10 | NR | | 2.3 | 1.1–2.3 | <0.001 Multivar RR 1.9 (1.3–2.9)
Folsom (10) | >0.90 | 0.14 | NR | | 2.5 | 1.6–3.2 | <0.001 Multivar RR 1.9 (1.3–2.9)
Folsom (10) | | [underlined: Other CVD Mortaltiy]
Folsom (10) | < 0.76 | 0.07 | NR | NR | 1 | | 0.003 Multivar RR 1.4 (0.9–2.1)
Folsom (10) | 0.76- 0.81 | 0.09 | NR | | 1.2 | 0.8–1.8 | 0.003 Multivar RR 1.4 (0.9–2.1)
Folsom (10) | 0.81–0.85 | 0.09 | NR | | 1.2 | 0.8–1.8 | 0.003 Multivar RR 1.4 (0.9–2.1)
Folsom (10) | 0.85–0.9 | 0.10 | NR | | 1.2 | 0.8–1.8 | 0.003 Multivar RR 1.4 (0.9–2.1)
Folsom (10) | >0.90 | 0.14 | NR | | 1.7 | 1.2–2.4 | 0.003 Multivar RR 1.4 (0.9–2.1)
Folsom (10) | | Cancer Mortality
Folsom (10) | < 0.76 | 0.28 | NR | NR | 1 | | 0.003 Multivar RR 1.2 (0.9–1.4)
Folsom (10) | 0.76- 0.81 | 0.31 | NR | | 1.1 | 0.9–13 | 0.003 Multivar RR 1.2 (0.9–1.4)
Folsom (10) | 0.81–0.85 | 0.37 | NR | | 1.2 | 1.0–1.5 | 0.003 Multivar RR 1.2 (0.9–1.4)
Folsom (10) | 0.85–0.9 | 0.36 | NR | | 1.2 | 1.0–1.4 | 0.003 Multivar RR 1.2 (0.9–1.4)
Folsom (10) | >0.90 | 0.40 | NR | | 1.3 | 1.1–1.6 | 0.003 Multivar RR 1.2 (0.9–1.4)

Study Examining % Body Fat and (Total) Mortality
Reference | Baseline %BF | Incidence | 95% CI | p (incidence) | Relative Risk | 95% CI | p (RR)
Heitmann (76) | % Body Fat (quintile mean)
Heitmann (76) | 25.7 | NR | | NR | 1.0 | | NR
Heitmann (76) | 28.2 | NR | | | 1.2 | | NR
Heitmann (76) | 30 | NR | | | 1.0 | | NR
Heitmann (76) | 32 | NR | | | 1.3 | | NR
Heitmann (76) | 35.3 | NR | | | 1.5 | 1.1–2.0 | NR

NR = Not reported

WC = Waist Circumferance

WHR = Waist:Hip Ratio

BF = Body Fat

PY = Person-Years

Less data examined the relationship between central obesity (measured by WC or WHR) and long-term all-cause mortality risk. One study (baseline age ≥ 65; no mean noted) assessed BMI, WC, WHR, and total mortality (adjusted for multiple factors including age, family history, and smoking); all three showed U-shaped relationships of relative risk, no overall trend, and no difference in risk between the largest and smallest weight categories. [67] However, measures of central (versus general) adiposity showed higher estimates of relative risk: compared to participants in the lowest adiposity quintiles (BMI: < 23 kg./m^2^; WC < 34.5 inches; or WHR <0.9), those in the largest quintiles (BMI ≥ 30 kg./m^2^; WC ≥ 40.3 inches; WHR ≥ 0.98) showed relative risks of 0.85, 1.17, and 1.08 respectively. [67]

[underlined: All Cause Mortality in Women:] In women, seven studies found U-shaped relationships between BMI and point estimates of subsequent long-term mortality (Table 5). [10] [70, 72] [74] [68, 79] [80] In two age-specific studies, a similar age effect was seen as for men, with obesity generally associated with increased risk of mortality, but with smaller relative risk among older participants. [68] [80] Relative risks were overall slightly lower than men’s. Three other studies examined all-cause mortality using a mid-BMI reference range. [79] [70] [72] Of these, one (baseline age range 55–84) found the largest participants had significantly increased mortality risk; [79] one (baseline age 65–74) found increased risk only among white participants; [70] and one (mean baseline age 70) found no statistical increase in risk. [72] Two studies compared the risk of largest versus smallest participants; one showed no significant difference [10] and the other found the obese had lower risk of all-cause mortality. [74] Four studies assessing for trend across baseline BMI showed borderline [10] or significant [72] [74] [79] effects.

WC showed U-shaped relationships with all-cause mortality in two studies with broad baseline age ranges. [10, 67] One study illustrated a borderline but significant effect between largest and smallest quintiles, and a significant trend across baseline WC. [79] The second, also using the smallest participants as referent, was not significant. [67] Notably, WHR showed a different risk pattern in one of these studies – a fairly linear, positive (versus U-shaped) statistically significant increase in mortality risk with increasing WHR. [10] In this study (adjusted for multiple factors including age, education, physical activity, tobacco, hypertension, and diet), relative risk was consistently higher for central measures of adiposity (WC, WHR) than for BMI. Compared to participants in the lowest adiposity quintiles (BMI: < 22.8 kg./m^2^; WC < 74.3 cm; WHR <0.76), those in the largest quintiles (BMI ≥ 30.2 kg./m^2^; WC ≥ 96.3 cm; WHR ≥ 0.90) showed relative risks of 0.91, 1.3, and 1.5 respectively. [10]

[underlined: Cardiovascular-Related Mortality in Men:] Disease-specific mortality also varied across studies and between adiposity measures (Table 5). Five studies showed generally U-shaped relationship between BMI and cardiovascular-related mortality in the old, [67, 73–75, 82] and one showed a generally linear, positive relationship. [80] All relative risk estimates from these studies used the lowest quartile or quintile as referent and did not find any difference in risk between thinnest and most overweight participants. Trend in risk across baseline BMI was generally non-significant. [67, 74, 75] WC was a better predictor of cardiovascular-related mortality than BMI in one study (baseline age ≥ 65 years): coronary heart disease mortality increased directly (versus in a U-shaped pattern) with WC, with the largest participants (WC ≥ 40.3 inches) being 3.5 times (CI 1.6–7.7) more likely to die from cardiovascular disease than those with the smallest waist (<34.5 inches). [67] Disease-specific mortality relationships with WHR were reported in only one study, and were non-significant after age 84. [80]

[underlined: Cardiovascular-Related Mortality in Women:] Similar patterns were found for disease-specific mortality as in men, though in the female studies, BMI at times showed U-shaped [74] [10] (cardiovascular disease), [10]at times negative (coronary heart disease), [74] and at times positive (ischemic heart disease, cardiovascular mortality) [78] relationships with cardiovascular-related risk (Table 5). These different relationships do not parallel age differences between the studies. As with men, some data suggest central adiposity has a more linear relationship with cardiovascular mortality than does generalized obesity. In one study, coronary heart disease mortality (but not “other cardiovascular disease” mortality) showed a statistically significant, generally positive, relationship with both WC and WHR (versus the U-shaped relationship seen in the same participants according to baseline BMI). [10] In this study, WC and WHR showed consistently higher relative risk estimates for CHD mortality than BMI. For example, among the largest quintiles, relative risk of coronary heart disease mortality (compared to the smallest quintiles) was 2.6 assessed by WC (CI 1.9–3.6), 2.5 assessed by WHR (CI 1.6–3.2), and 1.6 assessed by BMI (CI 1.2–2.2).

[underlined: Cancer Mortality:] We found little evidence for a link between BMI, WC, or WHR and cancer death in the elderly (Table 5). Three studies found no association between BMI and all cancer death, [78] [77] [67] or death from liver cancer. [77] One study in women showed a U-shaped relationship with a borderline significant trend between cancer mortality and BMI, no clear relationship between cancer mortality and WC, and a statistically significant positive relationship with WC. [10]

[underlined: Other Disease-Specific Mortality:] One study assessed hip fracture mortality by baseline BMI (Table 5). In women between the ages of 60–69, a U-shaped relationship was seen, with obese women having an 18% lower rate of fatal fracture than those with a BMI less than 24.3 kg./m^2^. Women aged 70–89 years and men aged 60–89 years showed a negative, generally linear relationship between baseline BMI and fatal hip fracture, with the quartile of largest participants (BMI >29–30 kg./m^2^ in women; >27–28 in men) showing approximately one half the risk of the quartile of smallest participants (< 23–24 kg./m^2^ in women; < 22–23 kg./m^2^in men). [83]

Finally, one study found that death from respiratory disease showed a negative, statistically significant relationship with WHR. [67]

#### III.A.3.ii Morbidity risk and different measures of obesity

Excess body weight (overweight to obese), as measured by BMI or WC, was significantly linked with incident stroke [66] [71] in men, but not women (Table 6). In one study, people with BMI above 27 were approximately 70% more likely to experience incident coronary heat disease. [47] Likewise, in a large group of US women, diabetes incidence was strongly linked with baseline adiposity, with a U-shaped pattern between baseline BMI and relative risk (RR for BMI > 30.2 kg./m^2^ versus <22.8 kg./m^2^: 13.8, CI 10.6 to 17.8) and a positive linear pattern for WC (RR for WC > 96.3 cm. versus <74.3 cm: 16.5, CI 9.0 to14.6) or WHR (RR for WHR ≥ 0.9 versus <0.76: 11.5, CI 9.0 to 14.6). Hypertension increased linearly with any of the diagnostic measures (relative risk for the same categories: 2.2 (CI 2.0–2.4), 2.3 (CI: 2.1 to 2.5), and 2.0 (CI 1.8 to 2.2) respectively).

Table 6 Summary of studies examining relationships between a) BMI b) Waist Circumference, and c) Waist to Hip Ratio and prospective morbidity risk

Reference | Baseline BMI | Incidence | 95% CI | p (Incid) | Relative Risk | 95% CI | P (RR)
Studies Examining BMI and Morbidity
Abbot (66) | 1st Thrombo-embolic CVA (#/1000)
Abbot (66) | 15.33–22.31 | 28.70 | NR | <0.01 | 27.2 | NR | NR
Abbot (66) | 22.32–24.71 | 40.70 | NR | | 42.2 | NR | NR
Abbot (66) | 24.75–35.96 | 54.26 | NR | | 55.4 | NR | NR
Cerhan (69) | Prostate Cancer Incidence (Cases/100 PY)
Cerhan (69) | <23.6 | 0.80 | NR | NR | 1 | | 0.1
Cerhan (69) | 23.6–25.8 | 0.67 | NR | | 0.9 | 0.5–1.9 | 0.1
Cerhan (69) | 25.9–27.8 | 0.80 | NR | | 1.2 | 0.6–2.5 | 0.1
Cerhan (69) | >27.8 | 1.07 | NR | | 1.7 | 0.8–3.3 | 0.1
Cerhan (84) | Non-Hodgkins Lymphoma: Cases/100 PY
Cerhan (84) | <23.5 | 0.06 | NR | NR | 1 | | NR
Cerhan (84) | 23.5–26.1 | 0.05 | NR | | 0.7 | 0.5–1.0 | NR
Cerhan (84) | 26.2–29.7 | 0.05 | NR | | 0.9 | 0.6–1.2 | NR
Cerhan (84) | ≥ 29.8 | 0.07 | NR | | 1 | 0.7–1.4 | NR
Dey (71) | 1st CVA: WOMEN
Dey (71) | ≤ 23.2 | NR | | NR | 1 | | NS (linear & nonlinear)
Dey (71) | 23.3–25.5 | NR | | | 0.96 | .66–1.38 | NS (linear & nonlinear)
Dey (71) | 25.6–28.5 | NR | | | 0.86 | .59–1.26 | NS (linear & nonlinear)
Dey (71) | ≥28.6 | NR | | | 1 | .69–1.45 | NS (linear & nonlinear)
Dey (71) | 1st CVA: MEN
Dey (71) | ≤ 23.3 | NR | | NR | 1 | | 0.006 linear (Nonlinear NS)
Dey (71) | 23.4–25.6 | NR | | | 1.27 | .83–1.95 | 0.006 linear (Nonlinear NS)
Dey (71) | 25.7–28 | NR | | | 1.35 | .89–2.05 | 0.006 linear (Nonlinear NS)
Dey (71) | ≥ 28.1 | NR | | | 1.68 | 1.12–2.53 | 0.006 linear (Nonlinear NS)
Folsom (10) | Diabetes Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 1.9 | 1.4–2.5 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 2.9 | 2.2–3.6 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 6.6 | 5.0–8.5 | <0.001
Folsom (10) | >30.21 | NR | | | 13.8 | 10.6–17.8 | <0.001
Folsom (10) | Hypertension Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 1.1 | 1.0–1.3 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 1.4 | 1.2–1.5 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 1.7 | 1.6–1.9 | <0.001
Folsom (10) | >30.21 | NR | | | 2.2 | 2.0–2.4 | <0.001
Folsom (10) | Hip Fracture
Folsom (10) | < 22.8 | NR | | NR | 1 | | 0.002
Folsom (10) | 22.80–24.87 | NR | | | 0.61 | 0.5–0.8 | 0.002
Folsom (10) | 24.87–27.06 | NR | | | 0.63 | 0.5–0.8 | 0.002
Folsom (10) | 27.06–30.21 | NR | | | 0.62 | 0.5–0.8 | 0.002
Folsom (10) | >30.21 | NR | | | 0.64 | 0.5–0.8 | 0.002
Folsom (10) | Any Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 0.95 | 0.9–1.1 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 0.97 | 0.9–1.1 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 1.0 | 0.9–1.1 | <0.001
Folsom (10) | >30.21 | NR | | | 1.2 | 1.1–1.3 | <0.001
Folsom (10) | Breast Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 1.2 | 0.97–1.4 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 1.2 | 0.99–1.4 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 1.3 | 1.1–1.5 | <0.001
Folsom (10) | >30.21 | NR | | | 1.4 | 1.2–1.7 | <0.001
Folsom (10) | Colon Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 0.93 | 0.7–1.3 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 1.2 | 0.9–1.6 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 1.3 | 0.99–1.8 | <0.001
Folsom (10) | >30.21 | NR | | | 1.5 | 1.1–2.0 | <0.001
Folsom (10) | Lung Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 0.59 | 0.4–0.8 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 0.44 | 0.3–0.6 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 0.45 | 0.3–0.6 | <0.001
Folsom (10) | >30.21 | NR | | | 0.40 | 0.3–0.5 | <0.001
Folsom (10) | Uterine Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 22.80–24.87 | NR | | | 0.94 | 0.6–1.5 | <0.001
Folsom (10) | 24.87–27.06 | NR | | | 1.0 | 0.7–1.6 | <0.001
Folsom (10) | 27.06–30.21 | NR | | | 1.4 | 0.95–2.2 | <0.001
Folsom (10) | >30.21 | NR | | | 3.5 | 2.5–5.1 | <0.001
Folsom (10) | Ovarian Cancer Incidence
Folsom (10) | < 22.8 | NR | | NR | 1.0 | | 0.27
Folsom (10) | 22.80–24.87 | NR | | | 0.95 | 0.6–1.6 | 0.27
Folsom (10) | 24.87–27.06 | NR | | | 0.68 | 0.4–1.2 | 0.27
Folsom (10) | 27.06–30.21 | NR | | | 1.2 | 0.7–1.9 | 0.27
Folsom (10) | >30.21 | NR | | | 1.2 | 0.7–2.0 | 0.27
Harris (47) | CHD Incidence
Harris (47) | <23.47 | NR | | NR | 1 | | NR
Harris (47) | 23.47–27.28 | NR | | | 1.1 | 0.7–1.8 | NR
Harris (47) | >27.28 | NR | | | 1.7 | 1.1–2.5 | NR
Harris (47) | <23.97 | NR | | NR | 1 | | NR
Harris (47) | 23.97–26.96 | NR | | | 1.4 | 0.7–2.2 | NR
Harris (47) | >26.96 | NR | | | 1.7 | 1.1–2.7 | NR
Launer(9) | Incident Mobility Disability (cases/100,000 pop)
Launer(9) | ≤ 23.8 | 3476 | | NR | 1 | | NR
Launer(9) | 23.81–28.10 | 4169 | | | 1.31 | 0.82–2.08 | NR
Launer(9) | ≥ 28.10 | 5031 | | | 2.04 | 1.20–3.48 | NR
Olson (64) | Lung Cancer Cases/100 PY
Olson (64) | <22.89 | 0.00 | NR | <0.001 | 1 | | <0.001
Olson (64) | 22.90–25.04 | 0.19 | | (trend) | 0.92 | 0.72–1.16 | <0.001
Olson (64) | 25.05 – 27.43 | 0.14 | | | 0.76 | 0.58–0.98 | <0.001
Olson (64) | 27.44–30.69 | 0.10 | | | 0.69 | 0.52–0.90 | <0.001
Olson (64) | ≥ 30.70 | 0.09 | | | 0.66 | 0.50–0.89 | <0.001
Studies Examining Waist Circumference and Morbidity
Dey (71) | 1st CVA: WOMEN
Dey (71) | ≤ 78 cm | NR | | NR | 1 | | NS (linear and nonlinear)
Dey (71) | 79–85 | NR | | | 1.16 | 0.81–1.67 | NS (linear and nonlinear)
Dey (71) | 86–93 | NR | | | 1.18 | 0.80–1.71 | NS (linear and nonlinear)
Dey (71) | ≥ 94 cm | NR | | | 1.31 | 0.88–1.92 | NS (linear and nonlinear)
Dey (71) | 1st CVA: MEN
Dey (71) | ≤ 84 CM | NR | | NR | 1 | | 0.004 linear (Nonlinear NS)
Dey (71) | 85–91 | NR | | | 1.4 | 0.91–2.14 | 0.004 linear (Nonlinear NS)
Dey (71) | 92–98 | NR | | | 1.5 | 0.98–2.29 | 0.004 linear (Nonlinear NS)
Dey (71) | ≥ 99 | NR | | | 1.65 | 1.08–2.51 | 0.004 linear (Nonlinear NS)
Folsom (10) | Diabetes Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 1.7 | 1.2–2.3 | <0.001
Folsom (10) | 80–87.3 | NR | | | 3.4 | 2.5–4.6 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 7.2 | 5.5–9.6 | <0.001
Folsom (10) | >96.3 | NR | | | 16.5 | 12.6–21.7 | <0.001
Folsom (10) | Hypertension Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 1.1 | 1.0–1.3 | <0.001
Folsom (10) | 80–87.3 | NR | | | 1.5 | 1.3–1.6 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 1.8 | 1.6–2.0 | <0.001
Folsom (10) | >96.3 | NR | | | 2.3 | 2.1–2.5 | <0.001
Folsom (10) | Hip Fracture
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | 0.56
Folsom (10) | 74.3–80 | NR | | | 0.85 | 0.6–1.1 | 0.56
Folsom (10) | 80–87.3 | NR | | | 0.91 | 0.7–1.2 | 0.56
Folsom (10) | 87.3–96.3 | NR | | | 0.83 | 0.6–1.1 | 0.56
Folsom (10) | >96.3 | NR | | | 0.91 | 0.7–1.2 | 0.56
Folsom (10) | Any Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1,0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 1.1 | 0.96–1.2 | <0.001
Folsom (10) | 80–87.3 | NR | | | 1.0 | 0.9–1.1 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 1.1 | 1.0–1.2 | <0.001
Folsom (10) | >96.3 | NR | | | 1.4 | 1.2–1.5 | <0.001
Folsom (10) | Breast Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 1.4 | 1.1–1.7 | <0.001
Folsom (10) | 80–87.3 | NR | | | 1.2 | 1.0–1.5 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 1.4 | 1.2–1.7 | <0.001
Folsom (10) | >96.3 | NR | | | 1.7 | 1.4–2.0 | <0.001
Folsom (10) | Colon Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 0.82 | 0.6–1.1 | <0.001
Folsom (10) | 80–87.3 | NR | | | 1.1 | 0.8–1.5 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 1.1 | 0.8–1.5 | <0.001
Folsom (10) | >96.3 | NR | | | 1.5 | 1.1–2.0 | <0.001
Folsom (10) | Lung Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | 0.003
Folsom (10) | 74.3–80 | NR | | | 0.93 | 0.7–1.2 | 0.003
Folsom (10) | 80–87.3 | NR | | | 0.56 | 0.4–0.8 | 0.003
Folsom (10) | 87.3–96.3 | NR | | | 0.55 | 0.4–0.8 | 0.003
Folsom (10) | >96.3 | NR | | | 0.78 | 0.6–1.0 | 0.003
Folsom (10) | Uterine Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 74.3–80 | NR | | | 1.2 | 0.8–1.8 | <0.001
Folsom (10) | 80–87.3 | NR | | | 1.2 | 0.8–1.9 | <0.001
Folsom (10) | 87.3–96.3 | NR | | | 1.4 | 0.9–2.1 | <0.001
Folsom (10) | >96.3 | NR | | | 3.3 | 2.3–4.8 | <0.001
Folsom (10) | Ovarian Cancer Incidence
Folsom (10) | < 74.3 | NR | | NR | 1.0 | | 0.14
Folsom (10) | 74.3–80 | NR | | | 1.1 | 0.6–1.9 | 0.14
Folsom (10) | 80–87.3 | NR | | | 0.65 | 0.3–1.2 | 0.14
Folsom (10) | 87.3–96.3 | NR | | | 1.5 | 0.9–2.5 | 0.14
Folsom (10) | >96.3 | NR | | | 1.3 | 0.8–2.2 | 0.14
Olson (64) | Lung Cancer Incidence: Cases/100 person years
Olson (64) | ≤ 76.56 cm | 0.14 | NR | 0.004 | 1 | | 0.15
Olson (64) | 75.57–81.92 | 0.14 | NR | (trend) | 1.04 | 0.81–1.34 | 0.15
Olson (64) | 81.93–89.54 | 0.10 | NR | | 0.8 | 0.62–1.05 | 0.15
Olson (64) | 89.55–99.0 | 0.10 | NR | | 0.82 | 0.63–1.09 | 0.15
Olson (64) | ≥ 99 | 0.11 | NR | | 0.91 | 0.69–1.19 | 0.15
Studies Examining Waist to Hip Ratio and Morbidity
Cerhan (84) | Non-Hodgkins Lymphoma: Cases/100 PY
Cerhan (84) | <0.777 | 0.05 | NR | NR | 1
Cerhan (84) | 0.777–0.831 | 0.05 | NR | | 0.9 | 0.6–1.4 | NR
Cerhan (84) | 0.832–0.892 | 0.07 | NR | | 1.4 | 1.0–2.0 | NR
Cerhan (84) | ≥ 0.893 | 0.06 | NR | | 1.1 | 0.8–1.6 | NR
Folsom (10) | Diabetes Incidence
Folsom (10) | < 0.76 | NR | | NR | 1.0 | | <0.001
Folsom (10) | 0.76–0.81 | NR | | | 1.9 | 1.4–2.5 | <0.001
Folsom (10) | 0.81–0.85 | NR | | | 3.0 | 2.3–3.9 | <0.001
Folsom (10) | 0.85–0.9 | NR | | | 6.0 | 4.7–7.7 | <0.001
Folsom (10) | >0.90 | NR | | | 11.5 | 9.0–14.6 | <0.001
Folsom (10) | Hypertension Incidence
Folsom (10) | < 0.76 | NR | | NR | 1 | | <0.001
Folsom (10) | 0.76–0.81 | NR | | | 1.2 | 1.1–1.4 | <0.001
Folsom (10) | 0.81–0.85 | NR | | | 1.4 | 1.3–1.6 | <0.001
Folsom (10) | 0.85–0.9 | NR | | | 1.6 | 1.5–1.8 | <0.001
Folsom (10) | >0.90 | NR | | | 2.0 | 1.8–2.2 | <0.001
Folsom (10) | Hip Fracture
Folsom (10) | < 0.76 | NR | | NR | 1 | | 0.14
Folsom (10) | 0.76–0.81 | NR | | | 1.1 | 0.8–1.5 | 0.14
Folsom (10) | 0.81–0.85 | NR | | | 1.3 | 0.9–1.7 | 0.14
Folsom (10) | 0.85–0.9 | NR | | | 1.2 | 0.9–1.6 | 0.14
Folsom (10) | >0.90 | NR | | | 1.2 | 0.9–1.6 | 0.14
Folsom (10) | Any Cancer Incidence
Folsom (10) | < 0.76 | NR | | NR | 1 | | <0.001
Folsom (10) | 0.76–0.81 | NR | | | 1.0 | 0.9–1.1 | <0.001
Folsom (10) | 0.81–0.85 | NR | | | 1.1 | 0.98–1.2 | <0.001
Folsom (10) | 0.85–0.9 | NR | | | 1.1 | 1.0–1.3 | <0.001
Folsom (10) | >0.90 | NR | | | 1.3 | 1.2–1.4 | <0.001
Folsom (10) | Breast Cancer Incidence | | | | | | 0.002
Folsom (10) | < 0.76 | NR | | NR | 1 | | 0.002
Folsom (10) | 0.76–0.81 | NR | | | 1.0 | 0.9–1.2 | 0.002
Folsom (10) | 0.81–0.85 | NR | | | 1.0 | 0.8–1.2 | 0.002
Folsom (10) | 0.85–0.9 | NR | | | 1.2 | 1.0–1.4 | 0.002
Folsom (10) | >0.90 | NR | | | 1.3 | 1.1–1.5 | 0.002
Folsom (10) | Colon Cancer Incidence | | | | | | 0.007
Folsom (10) | < 0.76 | NR | | NR | 1.0 | | 0.007
Folsom (10) | 0.76–0.81 | NR | | | 0.89 | 0.7–1.2 | 0.007
Folsom (10) | 0.81–0.85 | NR | | | 0.95 | 0.7–1.3 | 0.007
Folsom (10) | 0.85–0.9 | NR | | | 1.2 | 0.9–1.6 | 0.007
Folsom (10) | >0.90 | NR | | | 1.3 | 0.97–1.7 | 0.007
Folsom (10) | Lung Cancer Incidence | | | | | | 0.26
Folsom (10) | < 0.76 | NR | | NR | 1 | | 0.26
Folsom (10) | 0.76–0.81 | NR | | | 1.0 | 0.8–1.5 | 0.26
Folsom (10) | 0.81–0.85 | NR | | | 1.2 | 0.9–1.6 | 0.26
Folsom (10) | 0.85–0.9 | NR | | | 1.0 | 0.7–1.4 | 0.26
Folsom (10) | >0.90 | NR | | | 1.2 | 0.9–1.7 | 0.26
Folsom (10) | Uterine Cancer Incidence | | | | | | <0.001
Folsom (10) | < 0.76 | NR | | NR | 1 | | <0.001
Folsom (10) | 0.76–0.81 | NR | | | 1.0 | 0.7–1.5 | <0.001
Folsom (10) | 0.81–0.85 | NR | | | 1.4 | 0.9–2.0 | <0.001
Folsom (10) | 0.85–0.9 | NR | | | 1.2 | 0.8–1.8 | <0.001
Folsom (10) | >0.90 | NR | | | 2.0 | 1.4–2.8 | <0.001
Folsom (10) | Ovarian Cancer Incidence | | | | | | 0.13
Folsom (10) | < 0.76 | NR | | NR | 1 | | 0.13
Folsom (10) | 0.76–0.81 | NR | | | 1.3 | 0.6–2.4 | 0.13
Folsom (10) | 0.81–0.85 | NR | | | 1.7 | 1.0–3.0 | 0.13
Folsom (10) | 0.85–0.9 | NR | | | 1.2 | 0.6–2.1 | 0.13
Folsom (10) | >0.90 | NR | | | 1.7 | 0.96–3.0 | 0.13
Olson (64) | Lung Cancer Incidence: Cases/100 PY
Olson (64) | ≤ 0.76 | 0.10 | NR | <0.001 | 1 | | 0.92
Olson (64) | 0.77–0.80 | 0.12 | NR | | 1.01 | 0.76–1.34 | 0.92
Olson (64) | 0.81–0.85 | 0.12 | NR | | 0.95 | 0.73–1.24 | 0.92
Olson (64) | 0.86–0.90 | 0.12 | NR | | 0.97 | 0.73–1.28 | 0.92
Olson (64) | >0.90 | 0.14 | NR | | 1 | 0.76–1.32 | 0.92

NR = Not reported

WC = Waist Circumferance

WHR = Waist:Hip Ratio

BF = Body Fat

PY = Person-Years

Incident cancer (all causes) was 20% more common among largest (versus smallest) quintiles of women in the same study (Table 6). A similar increas in risk was seen for breast and colon cancer, regardless of adiposity measure, and higher risk noted for uterine cancer (RR in largest versus smallest quintiles for BMI: 3.5, CI 2.5 to 5.1; WC: 3.3, CI 2.3 to 4.8; WHR: 2.0, CI 1.4 to 2.8). No relationship was seen between adiposity and ovarian cancer. Obesity, measured by BMI, appeared protective of lung cancer; [10, 67] risk disappeared after adjusting for multiple factors including smoking and physical activity. [64] In two other studies, non-significant U-shaped patterns were found between baseline BMI and both prostate cancer, [69] and non-Hodgkin’s lymphoma [84] incidence.

Finally, weight in a moderately-overweight-to-obese range was predictive of incident limitations in functional mobility, showing approximately 2-fold risk. [9] However, increasing BMI (but not WC or WHR) was protective for hip fracture incidence. This effect was not limited to the obese range: risk was reduced by about 40% for anyone with a BMI over approximately 23 kg./m^2^. [10]

Most longitudinal studies assessing body size and morbidity risk evaluated samples that were less than 70 years of age at baseline. Therefore, we were unable to assess for change in risk across old age.

### III.A.4 Efficacy of weight loss intervention by different measures of obesity

All the weight loss RCTs we identified used kilograms or pounds as the primary outcome measure (Table 7). Two also assessed BMI; [85] [86] none evaluated for change in central adiposity. In addition, among younger adults, available data suggest that weight loss (kg.) corresponds with BMI loss. [86] [85]

Table 7 Summary of Diet and Behavioral Therapy Randomized Controlled Trials

Citation | Goal^*^ Intensity Mode^§^ | Follow Up | Sample | Baseline Weight † | Groups | Weight Change | Delta ¶ | p-value | Secondary Outcomes | Drop Out | Quality
Allen (85) | L Mod/High DEB | 12 mo | 116 women s/p initial CABG without concurrent surgical procedures at a large E Coast teaching hospital | 29–30 | BT Standard advice BT Standard advice BT Standard advice | Kg. Change −2 −1 BMI Change −0.9 −0.3 Freq. BMI Loss 55.4% 53.8% | −1 −0.6 1.6% | NS NS NR | Quit smoking: 16% 5% NS | 16% | Fair
Chao (86) | L/M High DEB | 52 wk | 67 Women (TONE subset) | 31 | Intervention Control Intervention Control | Kg. Change −3.5 −0.9 BMI Change −1.33 −0.34 | −2.6 −0.99 | <0.001 <0.0001 | BMD decreased by 6.3 +/− 2.1 g/cm2×10^−4^ for each pound of weight loss | 20% | Fair
Fagerberg (14) | L NR∥ D | 3.3 yr | 112 Hypertensive men in a CVD study in Gothenberg Sweden | 27 | Diet/Lipids/Tob Control | Kg. Change −0.56 −0.31 | −0.26 | NS^**^ | Oral GTT 24.6 mmol/L 28.2 mmol/L p=0.008 (sum of pre & post serum BG) Lipids reported, but not noted here as the intervention included lipid-lowering agents for those with unmet treatment goals | 37% | Fair
Knowler (13) | L/M High DEB | 2.8 yr (mean) | Minorities overrepresented. Included 648 older adults (≥ 60 y/o); DM (but not weight) outcomes specific to this older group | 34 | Lifestyle Placebo | Kg. Change (entire group, not the older subset) −5.6 −0.1 | −5.5 | <0.001 | 71% (CI 51 to 83%) reduction in diabetes incidence in lifestyle vs. placebo | 7.5% | Good
Kostis (90) | L/M High DEB | 48 mo | 141 obese TONE participants at University of Medicine and Dentistry of New Jersey-Robert Wood Johnson Medical School center | | WT Loss Non-Wt Loss | −14.8 −5.4 | −9.4 | NS | Off antihypertensive medication: 23% wt loss and low Na, 17% wt loss, 15% low Na, 7% UC (p=0.012) Cardiovascular events: 10% wt loss and low Na, 15% wt loss, 11% low Na, 16% UC (NS) | 10% | Good
Kumanyika (89) | L/M High DEB | 30 mo (mean) | TONE participants at least moderately obese | | Wt Loss^‡^ Non-Wt loss Wt Loss^‡^ Non-Wt loss | −3.3 −1.4 −4.2 −0.9 | −1.9 −3.3 | <0.05 (Black) <0.001 (White) Ethnic Diff p=0.12 | HRs (Combined TONE endpoint) Total: 0.71 (CI: 0.58–0.88) Black: 0.74 (CI: 0.49–1.11) White: 0.72 (CI: 0.57–0.93) p for ethnic difference 0.92 | Black: 5% White: 10% | Good
Whelton (15) | L/M High DEB | 30 mo | 585 Obese participants (TONE) | Women: 32 Men: 30–31 | Wt Loss^‡^ Non-Wt loss Wt Loss^‡^ Non-Wt loss | Kg. Change −3.9 −0.9 Freq. 4.5 kg. Loss 44% 13% | −3.0 31% | <0.05 NR | HR for weight loss vs. usual care: 0.70 (0.57–0.87) Combined TONE endpoint: New hypertension, antihypertensive or cardiovascular event | 9–11% | Good

* Trial Types: L=Weight Loss; M=Maintenance of Weight Loss

† Weight: presented as baseline mean (or range) BMI unless otherwise noted.

‡ Components: D=Diet; E=Exercise; B=Behavioral Therapy

§ Mode of Intervention: G=Group-based; I=Individual-based

∥ NR = Not Recorded

¶ Delta = Weight Change in Intervention – Weight Change in Control group.

** NS = Not Significant (p≥0.05)

‡ Here wt loss group includes those with and without sodium reduction

### III.A.5 Summary of Findings

Overall, among office-based diagnostic tests for obesity, BMI and WC showed very similar correlation with body fat percentage in men and women. Correlation with body fat percentage was slightly lower for skin fold thickness measurements, and markedly diminished for WHR. Correlation between anthropometric measures and body fat percentage was somewhat lower than found in younger samples. Limited, but mixed data suggest this correlation may decrease throughout old age. [59] [60, 61] Further evaluation of validity and precision of these measures is limited by a lack of sensitivity, specificity, or predictive value calculations. While WC correlates closely with body fat percentage and aims to measure central adiposity, it showed low sensitivity when used as a single tool to identify older patients with either generalized (by BMI) or central (by WHR) obesity. [62] Gender did not appear to strongly affect these analyses’ diagnostic accuracy, but the utility of diagnostic measures may differ across ethnic/racial groups. For example, in one Hong Kong sample, quite low (non-obese) BMI values were linked with high body fat percentage; [61] this finding is consistent with data for younger Asian populations. [87] Alternatively, a large US study including substantial proportions of white, black, and Hispanic participants found no ethnic difference in WC cutoffs corresponding to a BMI of at least 30 kg./m^2^.

Data are mixed regarding the relative usefulness of WC or WHR in predicting long-term risk. BMI has been associated with the most health outcomes (supporting its clinical utility in the old); inconsistencies in BMI-mortality risk appear to be in part age-related. However, available data suggest that measures of central adiposity (WC or WHR) may be better predictors of total mortality and cardiovascular mortality and morbidity, as they exhibit more linear (versus U-shaped) relationships, and may identify people with higher degrees of relative risk than BMI across their respective ranges.

## III.B Can weight loss be used as a surrogate for improved net health outcomes? If so, how much weight loss and over what time period of time?

### III.B.1 Health risk associated with obesity in the elderly

As discussed in detail in section III.A.3, obesity has been associated with increasing risk of a number of adverse health states in the elderly, including both mortality and morbidity (Tables 5 and 6). Conversely it may be protective of hip fracture and lung cancer.

[underlined: Mortality Risk:] Among men and women, point-estimates of long-term all-cause mortality typically showed a U-shaped pattern with increasing BMI. [10] [70, 72] [67, 68] [74] [79] [80] [73] [76] This relationship’s inconsistent statistical significance appears largely a result of confounding by age or comparison of risk between the largest and smallest individuals, rather than between the largest individuals and ones with “healthy” baseline weight. All-cause mortality risk dampened with age and was typically much reduced or absent after approximately age 75 (age 85 among men in one study [61]). Limited data examining relationships between WC or WHR and all-cause mortality also typically showed U-shaped risk patterns [67, 10] (only one study found a linear pattern between WHR and all-cause mortality in women [10]), and showed higher estimates of relative risk, compared with BMI, across the examined range of baseline body size.

Point estimates of cardiovascular-related mortality risk typically was increased among men or women with general obesity (by BMI) when compared to those with “healthy” or “overweight” baseline status. [67, 73, 74, 75, 10, 82, 78] Some variance in findings and statistical significance was noted by outcome, across studies, and by sex. As with all-cause mortality, statistical or (in men) age-related related factors appear to explain much of this variance. In a single study, the relationship between BMI and cardiovascular-related death risk was evaluated according to age: it declined, and was absent after age 84 in men, and after age 74 in women.

In contrast to BMI, limited data indicate that baseline WC (and WHR in women; data are lacking for men) shows a positive, generally linear, relationship with long-term cardiovascular-related mortality risk. [67, 10] In addition, within samples relative risk for cardiovascular-related death was consistently greater across the range of baseline central obesity measures than across the baseline range of BMI.

We found little evidence for a link between BMI, WC, or WHR and cancer death in the elderly. Hip fracture mortality increased with decreasing BMI; in women, this pattern was stronger among the oldest participants. [64] Likewise, death from respiratory disease was lowest among those with elevated WC. [47]

[underlined: Morbidity Risk:] A number of measures of cardiovascular-related disease were linked with general or central baseline adiposity: stroke (only in men), [46] [52] coronary heart disease, [47] diabetes, and hypertension. [10] In one large female study, incident breast cancer, colon cancer, and uterine cancer were more common among the obese. [10] Obesity, however, may be protective against lung cancer. [64] No significant relationship was found between obesity and ovarian cancer, [10] prostate cancer, [49] or non-Hodgkins lymphoma. [65] Moderately-overweight-to-obese body weight was linked with about 2-fold risk of incident limitation in functional mobility. [8] Finally, a BMI over approximately 23 kg./m^2^ (in the middle of the “healthy” range) was protective of hip fracture.

### III.B.2 RCT evidence for change in health status with weight loss in the elderly

Randomized controlled trials of weight loss in the elderly report mixed health effects of weight loss (Table 7). Overall, intervention participants in trials with modest weight loss success showed improved glycemic control as well as lower incidence of an outcome combining hypertension and cardiovascular events. However, they showed diminished bone mineral density (see section III.D.2). Although additional health effects of weight loss in the elderly are likely, others have not been evaluated in an RCT setting.

## III.C Which elderly patients with obesity would experience an improved health outcome with weight loss treatment?

We used two approaches to identify people likely to benefit from weight loss therapy: (1) consideration of who is at risk for weight-related adverse outcomes, and (2) consideration of the features of those with demonstrated health improvement following weight reduction intervention.

### III.C.1 Characteristics of people with evidence for health risk associated with body weight

Data for long-term health effects of body weight in the aged were drawn from cohort studies of fairly diverse patient populations (Table 4). Average baseline age range was 60 to at least 96 years; as discussed above, relative risk of all-cause mortality was generally significant in a wide age range over 60 years, but the magnitude of the risk tended to be reduced or absent by age 75 (age 85 in one male sample). Both genders were reasonably represented with five female studies, [10] [9, 84] [64, 78] six male studies [66, 67, 69, 73, 75, 82] and ten studies where 43% to 79% of participants were female. [68, 70–72, 74] [76] [77] [79, 80, 83, 88] Fourteen analyses were US-based. [9, 10, 47, 64, 66–70, 73, 78–80, 84] Others were carried out in Scandinavian countries, [71, 72] [74, 76, 83] [88] England, [75] [82] or Italy. [77] Five studies noted entirely white populations [73, 78–80, 84]; one included 17% Black participants, [70] and one followed Japanese-Americans; [66] the rest did not report racial/ethnic composition. Most used community samples; about a quarter restricted their sample to participants who were generally healthy at baseline.

Overall, health risk associated with excess weight was established for men and women over the age of 60 years. Race-and ethnic-specific data were limited; conclusions largely apply to populations of European origin. While all-cause mortality risk was considerably elevated among 60–74 year olds, it was largely non-significant after age 74. Data were insufficient to establish whether morbidity risk changes across old age.

### III.C.2 Review of the characteristics of people for whom there is RCT evidence of benefit from weight loss

The best evidence for health status change accompanying intentional weight loss in the elderly comes from US-based studies with good gender and racial diversity (Table 7). [89] [15] [86] [13] [85] These patients were relatively healthy. In one trial all participants were glucose intolerant and therefore at high risk of diabetes. [13] In another, participants had hypertension controlled by a single antihypertensive medication as enrollment and no other significant co-morbidities. [12] Additional data reflect Swedish outpatients, [14] and US female inpatients following bypass grafting. [85]

### III.C.3 Summary of Findings

Older people with evidence of obesity-associated health problems (cardiovascular disorders, cancer, or functional decline) stand to benefit most from intervention, if such intervention will alter their weight-related risk. Evidence for benefit from intentional weight loss in the elderly from well conducted RCTs is currently limited to improved cardiovascular-related measures, while harms focus on bone loss.

Cardiovascular risk factors – including family history, diabetes, tobacco use, or dyslipidemia – can identify those at high risk for cardiovascular disease. Risk for cancer or functional limitation is more complicated and often requires individualized patient assessment. However, several cancers with obesity-linked incidence (e.g., breast and colon) do have clear, identifiable risk factors. Finally, osteopenia, osteoporosis, or its risk factors may help identify those with risk of fracture – e.g., those most likely to experience harm from purposeful weight loss.

Among the elderly, the all-cause mortality risk associated with obesity (and therefore any potential all-cause mortality related benefit) diminishes with age. While risk of all-cause mortality with obesity is much reduced or absent by the mid-70’s to early-80’s (possibly persisting longer in men), age-related alteration in disease-specific mortality or morbidity risk among the elderly is largely unknown. In addition, RCT evidence for clinical benefits of weight loss is based on a select sample, including reasonable gender and racial diversity, but lacking ethnic diversity. These trials focused on patients who were moderately overweight to mildly (Stage I) obese, and often with at least one cardiac risk factor, but without substantial co-morbidities; the generalizability of findings beyond this group is unclear.

## III.D Are there dietary or behavioral therapies that improve net health outcomes in obese elderly?

### III.D.1 Evaluation of evidence for dietary or behavioral therapy leading to weight loss in the elderly

We identified seven RCTs meeting eligibility criteria (Table 7). Because all dietary studies except one incorporated behavioral components, the two treatment modes are discussed jointly here. Four of the included studies [86] [15] [89] [90] analyzed data from the Trial of Non-Pharmacologic Interventions in the Elderly (TONE) study. To better compare across studies, we assessed treatment mode (diet, exercise, and behavioral) and intensity (based on frequency of encounter in the first 3 months). [6] Interventions which met monthly were considered of moderate intensity; more frequent were considered high intensity and less frequent of low intensity. One study did not record information to assess treatment intensity; [14] one was considered moderate-to-high [85]; five (four based on TONE study participants) were of high intensity. [86] [15] [89] [13] [90] All except one [14] incorporated behavioral components. Effective interventions typically used diets based on reduced caloric intake, [12] often in the setting of low-saturated-fat and low-cholesterol intake goals. [13]

Internal validity of the included studies was fair [14] [85] [86] to good. [13] [15] [89] [90] Problems included high attrition (7.5 to 37%) and insufficient adjustment for potential confounders. In addition, studies generally did not report adverse effects of treatment. Most studies were based on US participants. [15, 89] [13, 86] [85] One focused on men, [14] two on women, [85] [86] and three included both. [13] [15] [89] Participants were generally fairly healthy and, when recorded, baseline age was typically in the 60’s. Duration of follow-up was 1 to 3.3 years.

All high-intensity interventions showed statistically significant weight loss. [86] [15] [89] [13] Over 1–2.5 years, the TONE study, incorporating behavioral and exercise components, showed significant (p<0.05) average weight loss over placebo. One analysis showed an average 2.6 kg. loss after one year; one an average 3 kg. loss after 2.5 years; the third, stratified by race, a 3-year loss of 1.9 kg. among black participants and 3.3 kg. among white participants. One TONE analysis reported frequency of clinically significant weight loss (≥ 4.5 kg.): 44% of those treated with the weight loss intervention versus 13% not counseled for weight loss (significance not reported). [15] The other (non-TONE) high-intensity intervention study’s participants were aged 25 or above, with 20% of participants over the age of 60. While this study did not report age stratified weight results, it did show a significant weight loss (5.6 vs. 0.1 kg., p<0.001) in the entire sample over a mean of 2.8 years. [13]

The single study that evaluated a moderate-to-high-intensity behavioral approach did not show a statistically significant outcome. [85] The study examining diet without exercise or behavioral interventions was likewise not successful. [14] This study did not provide adequate information to assess intervention intensity. Results of both non- significant trials are difficult to interpret, as tobacco cessation is a potential confounder: both showed higher (but not statistically significant) quit rates in the intervention groups than the control: 16% versus 5% in one, [85] and 32% versus 12% in the other. [14]

No studies evaluated long-term maintenance interventions. However, one analysis of TONE data showed that at four years of follow-up (approximately two years after discontinuing intervention), the difference in weight change between weight loss and control groups was no longer statistically significant. [90]

### III.D.2 Health status change with intentional weight loss or dietary therapies

The RCTs of weight loss intervention that reported health outcomes in addition to weight change focused on cardiovascular-related endpoints. Two dietary RCTs considered glycemic outcomes. In one, 20% of the overall group was over the age of 60; age-specific weight loss was not presented. Overall mean weight loss in the lifestyle intervention was 5.5 kg. beyond control after 2.8 years; elders in the lifestyle group showed a 71% reduction in diabetes incidence (CI 51 to 83%) compared with the placebo group. [13] Among those aged 45–59 years, corresponding diabetes reduction was only 59% (CI 44 to 70%). In another diet-only study of Swedish men, although there was no net weight change in intervention versus control participants, the sum of pre-and post-serum blood glucose from an oral glucose tolerance test was significantly lower in the intervention versus control group (sum of pre- and post- blood glucose concentrations: 24.6 +/− 3.9 mmol/L vs. 28.2 +/− 10.2 mmol/L). [14]

Two analyses of the TONE data considered a combined endpoint of either poorly controlled blood pressure, re-initiation of antihypertensive medications, or a cardiovascular surgery or event. [15] [89] They found an average 3.0 kg. weight loss corresponding to an approximately 30% reduction (RR 0.70, CI 0.57–0.87) in combined outcome after 2.5 years. [15] [89] When these authors stratified by race, trends were similar, but non-significant, likely due to sample size limitations; they found no significant ethnic difference in incidence of the combined outcome (white: HR 0.72, CI 0.57 to 0.93; black: HR 0.74, CI 0.49–1.11). [89] A four year follow-up from the TONE study showed that although weight change was no longer significant, some benefit persisted in terms of hypertension: 17% of those in the weight loss group versus 7% of those in the usual care group had not needed re-initiation of antihypertensive medication. The two groups did not differ in cardiac event rate, but were not powered for this outcome. [90]

Another TONE sub study considered bone implications of weight loss in a subset of women: a 2.6 kg. loss corresponded to a decrease in bone mineral density (BMD) (0.00063 +/− 0.00021 g/cm^2^ for each pound of weight loss). As the risk of hip fracture increases directly with age, and inversely with BMD, this finding may be clinically significant. [91] While the degree of BMD change is unlikely to have a large impact over the typical range of diet-induced weight loss (sustained 8 kg. of weight loss corresponds to 0.01 g/cm^2^ decrement in BMD), for those at high risk of osteoporosis, it could be important.

### III.D.3 Limitations and conclusions

Diet and behavioral treatment results are drawn from relatively few RCTs examining older adults. The findings, however, are very consistent with efficacy trials enrolling younger participants. [6] Intensity of intervention and a multifaceted approach (diet, behavioral, exercise) appear linked with intervention success. High-intensity dietary intervention, delivered with behavioral approaches and incorporating physical activity, led to about 3 kg. of weight loss. White participants generally lost slightly more weight than African American ones. The modest weight change seen with such diet and exercise interventions was associated with beneficial health outcomes, including glycemic improvement and diabetes prevention. [13, 14] Similarly, improved cardiovascular risk, as assessed by incidence of a composite outcome (based on blood pressure control and cardiovascular events), was reported. [15] [89] Notably, there are also negative effects of intentional weight loss in the aged: bone mineral density loss showed a significant linear decline with weight loss in one study.

## III.E Are there surgical therapies that improve net health outcomes in obese elderly?

Bariatric surgery is restricted to patients with BMI > 40 or BMI ≥ 35 with associated health complications and past failure to respond to other treatment modalities. [92] Common procedures are either restrictive or malabsorptive, and include gastric bypass, adjustable gastric banding, vertical banded gastroplasty, and the duodenal switch procedure.

We identified no RCTs evaluating surgical obesity treatment in the elderly (Table 1). In the younger population, surgery can promote large degrees of weight loss (18–36 kg.), over a prolonged (18–36 months) period of time. [3, 4, 57, 93] [6] [54] Data must be interpreted with caution, however, as there are practical and ethical constraints to RCT study designs. These data reflect randomized trials comparing more than one procedure, and non-randomized controlled studies.

Surgical weight loss has been accompanied by marked improvements in a number of health outcomes including diabetes (improved blood glucose control or resolution of diabetes), hypertension (although there some data indicate that hypertension resolution is transient), dyslipidemia, and quality of life. [6, 93] [6] While bariatric surgery complications are infrequent, they can be severe, including death. As chronic illness increases with age, and both age and co-morbidity have been linked with peri-operative risk, [94–96] relatively low rates of adverse surgical outcomes based on younger populations may not generalize to the older group.

Overall, there are insufficient data to support the efficacy and safety of bariatric surgery among the elderly at this time. We draw this conclusion from the lack of bariatric efficacy and adverse effect data in the elderly, coupled with increased likelihood of adverse outcomes with age itself, and with the co-morbidities that tend to accompany obesity with age.