# Methods

In this review we address five policy-relevant tasks posed by CMS and AHRQ: (1) Is BMI alone an adequate diagnostic test for obesity in the elderly or should another measurement be combined with or used instead of BMI?; (2) Can weight loss be used to predict improved health outcomes?; (3) Which obese elderly patients would experience improved health outcomes with weight reduction?; (4) Can dietary or behavioral therapies improve health outcomes in obese elderly?; (5) Can surgical therapies improve health outcomes in the obese elderly?

Key questions were adapted from an analytic framework for obesity treatment in the general adult population, [6] and address each step in the process from population at risk, diagnosis, treatment, and changes in intermediary and ultimate health outcomes. In answering these specific questions, we address a discrete subset of knowledge regarding body weight in the old. In order to capture all information pertinent to these questions for the aging population in the setting of limited data, we considered information on adults of at least 60 years of age (mean baseline age).

We defined obesity-related health outcomes to include: (1) mortality; (2) morbidity; including quality of life and function; and, (3) well-established intermediate outcomes of cardiovascular disease, such as glycemic control, blood pressure, and lipids. [55, 56] We were primarily interested in whether interventions could lead to improvements in the former, however, data on a number of pertinent health outcomes (e.g., cardiovascular events, cancer incidence, and death) are lacking because they require long-term follow-up or large sample sizes. Therefore, we followed the model of other analyses assessing effectiveness of counseling interventions, and also examined the ability of intervention to affect intermediate health outcomes. [58]

We considered randomized controlled trials (RCTs) or systematic reviews of RCTs preferred evidence; when lacking, we evaluated other evidence such as cohort studies. [7] Evidence strength and study internal validity (Appendix 2) were rated using standard criteria. [7] [8] Because weight loss peaks at 6-months and tends to be transient, [3, 4] we excluded RCTs with less than 1-year of follow-up.

To determine long-term health implications of body weight, we considered cohort data for groups with at least 10 years of follow-up. Quality ratings of these observational studies included considerations of potential confounders identified in the medical literature: (1) we felt that adjusting for tobacco use was important, as smoking can both directly (by influencing appetite and eating patterns) and indirectly (by a causal role in chronic disease) alter weight dynamics; (2) because diet and exercise are primary mediators of obesity development, and we were interested in the net effect of obesity on health, we preferred relative risk estimates unadjusted for these factors; and, (3) we preferred exclusion of early deaths in studies examining mortality, to minimize the possibility that baseline weight, especially low weight (underweight), reflects abnormal weight dynamics due to concurrent disease.

We searched MEDLINE and the Cochrane Library for articles published in English between January 1980 and February 2003. We also reviewed bibliographies of published reviews to identify additional articles. Searches were limited to human population and English language. At least two authors independently reviewed abstracts and articles, excluded those not meeting eligibility criteria, and then retrieved eligible articles. If either reviewer felt an abstract met eligibility criteria, the article was obtained for review and data were abstracted into a standard abstraction form.

We examined evidence tables from well-done, prior systematic reviews of clinical approaches to obesity in the general population [3] [4] [54, 57] to identify any additional articles meeting our inclusion criteria. When these tables provided incomplete data to assess relevance, we obtained the primary literature for review. For topics on which insufficient data were available to assess key questions in the elderly, we drew from conclusions of these prior reviews in the general population. All data were synthesized into evidence tables and conclusions drawn from the aggregate findings.