# Discussion

## IV.A General Conclusions

Obesity is an increasingly common problem among US elderly, found in about a third of those aged 65 to 74 years, and 20–25% of those over the age of 74. Among the general adult population, there is good evidence to promote the diagnosis and treatment of obesity; respective findings are more complicated among the aged.

Diagnosis of obesity using anthropometric measures is easy and inexpensive. Although the correlation between BMI and fat mass is lower in older adults than in the general population, the difference is typically small. Data showing lower correlations among older men are limited and conflicting, while long-term health outcomes associated with BMI in the aged support its clinical utility. Two measures of central weight accumulation are also common: WC and WHR. Of the two, only WC correlates closely with body fat percent; limited data suggest both may be linked with higher relative risk of total or coronary heart disease mortality, as well as cardiovascular morbidity, than is BMI. At this time, data are insufficient to distinguish the relative utility of WC and WHR for identifying elderly persons with cardiovascular risk, but the ease of use of WC may make it more desirable. BMI, however, has been associated with a much wider range of health outcomes, including some (such as protection against fatal hip fractures) that are not linked to central adiposity. Likewise, RCTs evaluating sustained efficacy of lifestyle intervention in the elderly have measured success using either BMI or weight change (which is directly correlated with BMI). Therefore, use of a central adiposity measure should not replace BMI as a diagnostic tool, but rather be used as an adjunct particularly for the identification of those with cardiovascular risk.

To date, there are no RCT data evaluating the effect of weight loss interventions on long term mortality. However, intentional weight loss is a reasonable surrogate for certain improvements in health outcomes in the elderly. A number of measures of cardiovascular disease (mortality, morbidity, and incidence of intermediary outcomes) are not only prospectively linked with obesity in the elderly, but RCT evidence shows that counseling-based interventions (combining dietary, exercise, and behavioral components) can improve cardiovascular risk profile. For example, improved fasting glucose tolerance, decreased diabetes incidence, and a decreased combined cardiovascular-related endpoint (either high blood pressure, re-initiation of antihypertensive medication, or a cardiovascular event or surgery) are associated with intervention. Only modest weight loss (2 to 3 kg.), sustained over one to three years, was sufficient to produce these clinically meaningful results.

As long-term longitudinal data support an increased risk of cancer incidence (but not mortality) in obese women (data are lacking for men), intentional weight loss potentially may influence cancer morbidity among the obese elderly. Because weight loss RCTs have limited duration of follow-up, and most cancers do not have reliable intermediary outcomes, it is difficult to assess the effect of intentional weight loss on cancer incidence; current data do not address the question. Similarly, there is strong evidence for incident functional limitation with increasing BMI; RCTs in the elderly have not assessed functional improvement to date.

Both longitudinal data showing that obese BMI is linked with lower hip fracture incidence and hip fracture mortality rate in the elderly, and RCT evidence of declining bone mineral density with weight loss intervention suggest that intentional weight loss may be a marker for adverse bone consequences.

The obese elderly most likely to benefit from weight loss are those with cardiovascular-related disease, or those at high risk of such disorders. Those with high risk of cancer or functional decline would possibly benefit as well. Markers of cardiovascular risk – including age, family history, personal history of diabetes or hypertension, tobacco use, or dyslipidemia – have been well-defined, and can be used to identify a high risk group. Risk for any cancer is much more complicated. However several of the cancers with demonstrated obesity-linked incidence (e.g., breast, colon) have clear risk factors that could be identified clinically and are biologically plausible. Predicting functional limitation, however, is likely to require individualized physician assessment. Finally, osteopenia, osteoporosis, or its’ risk factors are likely to best identify those with risk of fracture – e.g., those most likely to experience harm from purposeful weight loss.

Observational data suggest that any potential mortality risk from obesity diminishes with age and is much reduced or absent by the mid-70’s to early 80’s. Change in disease-specific mortality risk or morbidity risk across old age, however, can not be accurately assessed from the current medical literature. Successful dietary weight loss intervention has focused on participants with a relatively young [12] or poorly defined [13] age range. In addition, while diet and behavioral RCTs included participants with reasonable gender and racial diversity, ethnic diversity was lacking. Trials focused on patients who were moderately overweight to mildly (stage I) obese, generally at risk for cardiovascular disease, but without substantial co-morbidities.

Obesity therapies shown in RCTs to improve health outcomes in the elderly incorporate both dietary and behavioral components. All successful studies also included exercise and were delivered with a high-intensity (based on frequency) approach. Average weight loss appeared slightly less (2–3 kg. versus 3–5 kg.) than among younger samples; this may reflect the limited number of studies. Clinical utility of this loss is supported by evidence for associated improved glycemic parameters, including improved oral glucose tolerance test values, as well as marked reductions in diabetes incidence among glucose intolerant individuals. [13] [14] Similarly, participants treated with an intensive intervention with diet, exercise, and behavioral components showed reduction in an endpoint combining hypertension and cardiovascular events or surgery; [15] improvements in hypertension control persisted over a year after discontinuation of intervention, though weight gain recurred. [90] While data in the elderly were very limited, findings are consistent with the much larger body of literature in the younger adult population. For example, data from the younger adult population suggest that intensive counseling techniques improve treatment efficacy, as does the combination of multiple modes of therapy. [6] Likewise, in younger adults, addition of long-term weight maintenance strategies has been shown to help sustain weight loss. We did not identify any RCTs evaluating such maintenance studies in older adults.

In this review we did not specifically evaluate physical activity or pharmacotherapy treatment options for obesity, as they were not considered policy options by CMS. However, physical activity has extensive health benefits, including potentially lessening the adverse health effects of obesity. [97] [98] In addition, exercise is an integral part of successful obesity lifestyle interventions in the elderly. Also, as weight bearing physical activity is protective of bone loss, [16] incorporation of exercise into weight loss programs may help offset bone risk.

Current data are insufficient to assess the efficacy or safety of bariatric surgery in the elderly. We identified no RCTs evaluating surgical obesity treatment in the elderly. In the younger population, surgery can promote large degrees of weight loss among a select group of patients. Its’ complications are infrequent, but can be severe, including death. As chronic illness increases with age, and both age and co-morbidity have been linked with peri-operative risk, [94–96] rates of adverse outcomes of surgery based on younger populations may not generalize to the older group.

## IV.B Future Research Topics

Consideration of the effectiveness of obesity diagnosis and treatment in the elderly is primarily limited by the lack of age-specific data in this field. Observational studies assessing health sequellae of obesity show a clear age-related gradient in total mortality risk, but such age-stratified analyses are lacking for disease-specific mortality, or for morbidity. As quality-of-life, morbidity, and health care costs are strongly influenced by these factors, such data are essential. Although available studies include well-done trials set in racially diverse populations, treatment efficacy data in the elderly are quite limited. Quality issues in some studies include high attrition, minimal reporting of harms, and sometimes inappropriate adjustment for potential confounders. No studies evaluated weight maintenance strategies in this group. Incorporation of greater ethnic diversity, and participants with higher stage obesity, as well as consideration of alternate measures of adiposity (e.g., WC, WHR), could add to understanding of the role of purposeful weight loss in elders’ health.

A better understanding is needed of both how obesity risk for morbidity and how benefit from intervention changes across old age. Notably, our searches included studies with mean baseline age of at least 60 years – findings based on samples at the lower end of this range may not generalize to the very old. Likewise, assessment of a wider array of health consequences with intentional weight loss is needed – including characterizing the mechanisms of functional improvement with loss (especially important given the high prevalence and costs of disability in the aged), long-term assessment of cardiovascular or cancer outcomes, and impact on health care costs. Finally all the dietary and behavioral interventions were efficacy trials; translation into clinical effectiveness is uncertain from these data.

The absolute lack of surgical RCT data makes this mode of treatment impossible to assess in the aged. Because safety concerns could be considerable, a first step may be analysis of existing data to determine adverse event rates in older bariatric surgery patients. If safe, it is potentially an important treatment mode for patients with extreme obesity.

As noted above, better characterization of the role of physical activity in weight loss and health in the elderly is needed. Similarly, the role of pharmacotherapy was not addressed here – as adverse effects of drugs are particularly problematic in the old, data from the younger population may not generalize to the old.

Finally, consideration of the net costs and benefits of obesity treatment in the elderly is essential in understanding the long-term policy implications of diagnosis and treatment strategies.