# Background

Prevalence of obesity, a disorder of body composition defined by a relative or absolute excess of body fat, [2] is increasing among older US adults, paralleling the rise seen in the general adult and youth populations. [1] [17] In the setting of epidemic prevalence trends, the 2002 Surgeon General’s Report establishes obesity as a health priority. [18] While older women are more likely to be obese then men, prevalence is increasing more rapidly among males: in 1960–1962, among US adults age 65–74, 10% of men and 23% of women were obese; 1999–2000 estimates are 33% and 39% respectively (Figure 1). [1] Over the age of 74, prevalence is lower, but still substantial: 20% of men and 25% of women in 1999–2000. These data reflect standard body weight definitions based on the Body Mass Index (BMI = kg./m^2^). A BMI of 18.5–24.9 is considered healthy, 25–29.9 is overweight, and ≥ 30 is considered obese. [3]

Figure 1 Obesity prevalence trends among US adults age 65–74. [1]

In the general adult population, obesity has been associated with a diverse array of adverse health outcomes, including major causes of death such as cancer, diabetes, cardiovascular disease, as well as functional impairment from problems such as osteoarthritis and sleep apnea. [3] A BMI of 30 kg./m^2^ reflects the point at which obesity confers about 2-fold mortality risk in the general adult population. [3] The distribution of fat also mediates its’ health implications. Central adiposity carries increased cardiovascular risk – even among the non-obese. [10, 19–22] In addition, visceral (versus subcutaneous) fat is particularly linked with adverse cardiovascular risk profiles in diverse ethnic/racial groups. [23] [24–29] In general, body composition varies with race/ethnicity; (e.g., Asians may be more likely [30] and African Americans less likely to accumulate visceral fat than Caucasians [24, 31, 32]) health implications may also vary. [29] [23–28]

Unique features of older Americans must be incorporated into consideration of obesity diagnosis, treatment benefits, and harms in this population. With aging, fat distribution shifts, potentially influencing both diagnostic accuracy of obesity tests and health risks. [33, 34] Central, versus peripheral fat accumulation, and the accumulation of deep fat relative to subcutaneous fat has been noted with aging. [35, 36] These changes may influence the accuracy of obesity diagnosis. Likewise, obesity treatment efficacy may be age dependent. As most obesity intervention trials focus on the middle-aged, efficacy and harms may not generalize to older populations.

Patterns of mortality and morbidity also vary with age, potentially influencing the health effects of intentional weight loss. Death rates rise with each decade of adult life and primary causes of mortality shift, with those associated with obesity becoming increasingly common. [1] [3] For example, among people 65 years of age or older, cardiovascular diseases surpass cancer as the top cause of death, and cerebrovascular disease displaces unintentional injuries as the third most common cause; [1] all three (though only certain cancers) are more common among the obese. [3] Hypertension prevalence increases with age (in 68% of men and 73% of women aged 65–74 years, versus 51% and 58% respectively, aged 55–64). Likewise, at age 60 or above, 19% of people have diabetes and another 15% impaired fasting glucose; prevalence drops to 9% and 6% respectively in those aged 40–59. [37]

Functional limitation becomes increasingly important with age: 61% of US adults aged 85 or above report limitations in functional activities, up from 20% at age 55–64. Limitation in activities of daily living increase markedly (27% versus 3%) over the same age range [38] as does arthritis (the leading cause of US disability); [39] about 60% of those over the age of 65 report chronic joint disease or arthritis [40]. Likewise, falls and fractures become prevalent. [41] With escalating obesity prevalence in the old, functional concerns may be particularly relevant as short-term and cross-sectional data suggest a link with obesity. [42] [43, 44]

Obesity carries considerable societal cost, with estimated direct obesity costs of 5.7% of total US health expenditures. [45] Expected lifetime costs for cardiovascular disease and its risk factors increase by 20% with mild obesity, 50% with moderate obesity, and nearly 200% with severe obesity. [46]

Understanding the potential health effects of weight loss intervention is complicated by observational studies examining all-cause weight loss. A number of such studies have noted associations between weight loss and increased all-cause mortality. [47] [48] [49] [50] [51] Such findings, however, usually reflect lack of discrimination between intentional and unintentional weight loss; even when recognized, volition is difficult to measure, and transient weight loss may be misclassified. [52] [34] As clinically significant weight loss in the elderly frequently occurs in the setting of disease or psychological distress (depression, gastrointestinal complaints, and cancer are the most common causes), [52] unintentional weight loss is an important confounder. [53] [47] [34] Adjusting or excluding those with unintentional loss may eliminate [53] or diminish [50] this risk – the latter potentially reflects measurement problems as noted above. In the setting of such conflicting data and confounding, the evidence-based medicine approach, focusing on randomized controlled trial (RCT) data over observational data, [7] is of particular importance for assessing the effects of [underlined: intentional] weight loss on health.

Options for intentional weight loss intervention include: counseling strategies for diet and/or exercise that often incorporate behavioral theory, as well as pharmacotherapy or surgery. Weight regain is a common problem which can be mitigated by long-term weight maintenance strategies. [3, 54] [4] [6] In the general adult population, counseling-based or pharmacologic treatment options are generally safe, and can lead to modest, sustainable improvements in weight sufficient for improving health measures such as glycemic control, lipids, and blood pressure. [3] [4] [5] [6] Improving these intermediaries may signal long-term cardiovascular benefit. [55, 56] Limited length of follow-up of weight-loss RCTs makes rigorous evaluation of changes in other health outcomes more difficult to assess. Surgical intervention, among the very obese, can produce substantial weight loss and marked improvement in blood pressure, lipid profile, glycemic control (including reversal of diabetes), and quality of life measures. [6] [3] [4, 57] Surgical data, though, are of lesser quality than counseling studies, and adverse events, while uncommon, can be serious, including death.

Thus, consideration of obesity treatment in the aged demands balancing multiple complex issues. The proportion of elderly with risk for diseases associated with obesity is considerable; if these risks improve with obesity treatment, intervention could have a large population effect. Among the frail, however, expected life span may be too limited to realize long-term health benefits of improving weight or cardiovascular intermediaries. Alternatively, any short-term improvement in functional status may substantially improve quality of life. Finally, accuracy of diagnosis and efficacy and harms of treatment are not well defined for older adults, and strongly influence the effects of intervention.

To determine how these factors interact among the aged, we conducted a systematic review of policy-relevant obesity diagnosis and treatment options.