# Search Strategies

## Task 1 Diagnosis of obesity in the elderly

a. Validity and reliability of diagnostic tests
b. How are the different measures of obesity associated with the incidence of adverse health outcomes in the elderly: [underlined: longitudinal studies] by baseline weight in studies from question 2.1
c. Review of which adiposity measures are linked with health risk in the trials reviewed in questions 2b, 4–6

Validity and Reliability of Diagnostic Tests

Search History
exp body mass index/ or exp anthropometry/ or exp body composition/ or exp skinfold thickness/
exp "Sensitivity and Specificity"/ or exp Predictive Value of Tests/ or positive predictive value.mp. or negative predictive value.mp.
exp reproducibility of results/ or validity.mp. or precision.mp.
2 or 3
1 and 4
limit 5 to (human and english language and yr=1980–2003)
exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp.
limit 6 to ("all aged <65 and over>" or "aged <80 and over>")
6 and 7
9 or 8
exp obesity/
exp DIAGNOSIS/
11 and 12
13 and 4
limit 14 to (human and english language and yr=1980–2003)
limit 15 to ("all aged <65 and over>" or "aged <80 and over>")
15 and 7
16 or 17

## Task 2 Does weight loss lead to improved health in the elderly? (how much weight and over how long?)

a. Does obesity entail health risk in the elderly? ([underlined: Longitudinal studies] search)
b. Does intentional weight loss in the elderly lead to improved health outcomes? – review of health outcome change in trials reviewed for questions 4–6; if no information from the elderly, draw inferences from the USPSTF searches.

Longitudinal Studies Search

Search History
exp body mass index/ or exp body composition/ or exp skinfold thickness/
exp Longitudinal Studies/
exp cohort studies/
2 or 3
1 and 4
limit 5 to (human and english language and ("all aged <65 and over>" or "aged <80 and over>"))
aged/ or postmenopause/ or geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp.
5 and 7
limit 8 to (human and english language)
9 or 6
limit 10 to yr=1980–2003

## Task 3 Which elderly patients with obesity would experience improved health outcomes with weight loss

a. review of the characteristics of those at highest risk from Longitudinal Studies above (2a)
b. review characteristics of the participants who show benefit in the RCTs reviewed for tasks 4–6.

## Task 4 Are there dietary therapies that improve net health outcomes in the obese elderly? (Include duration, circumstances, harms)

a. Are there dietary therapies that can lead to weight loss?
  Dietary Searches: Diagnostic Studies
  Search History
  exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
  exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
  1 and 2
  limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
  3 or 4
  limit 5 to (human and english language and yr=1980–2003)
  exp diet, reducing/ or exp diet/ or exp diet therapy/ or low calorie diet.mp. or exp vegetarianism/ or vegetarian diet.mp. or aha diet.mp. or aha guidelines.mp. or ncep.mp. or caloric restriction.mp.
  6 and 7
  exp mass screening/
  8 and 9
  Diet RCTs
  Search History
  exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
  exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
  1 and 2
  limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
  3 or 4
  limit 5 to (human and english language and yr=1980–2003)
  exp diet, reducing/ or exp diet/ or exp diet therapy/ or low calorie diet.mp. or exp vegetarianism/ or vegetarian diet.mp. or aha diet.mp. or aha guidelines.mp. or ncep.mp. or caloric restriction.mp.
  6 and 7
  exp "randomized controlled trials"/ or exp single-blind method/ or exp double-blind method/ or exp random allocation/
  8 and 9
  limit 8 to randomized controlled trial
  10 or 11
  Dietary Searches: Review Articles
  Search History
  exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
  exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
  1 and 2
  limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
  3 or 4
  limit 5 to (human and english language and yr=1980–2003)
  exp diet, reducing/ or exp diet/ or exp diet therapy/ or low calorie diet.mp. or exp vegetarianism/ or vegetarian diet.mp. or aha diet.mp. or aha guidelines.mp. or ncep.mp. or caloric restriction.mp.
  6 and 7
  limit 8 to review articles
  limit 8 to meta analysis
  9 or 10
b. Does intentional weight loss lead to improved health? (from 2b; same searches as for Task 4a but looking at health outcomes as available; if needed, refer to USPSTF general population findings)
c. Do dietary therapies lead to improved health? (evaluate health outcomes from the RCTs in dietary searches above)

## Task 5 Are there behavioral therapies that lead to weight loss?

Behavioral Therapy Diagnostic Studies

Search History
exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
1 and 2
limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
3 or 4
limit 5 to (human and english language and yr=1980–2003)
exp behavior/ or exp behavior therapy/ or exp goals/ or goal setting.mp. or self monitoring.mp. or exp self concept/ or behavior modification.mp. or exp cognitive therapy/ or cognitive behavior.mp.
6 and 7
exp mass screening/
8 and 9

Behavioral Therapy RCTs

Search History
exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
1 and 2
limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
3 or 4
limit 5 to (human and english language and yr=1980–2003)
exp behavior/ or exp behavior therapy/ or exp goals/ or goal setting.mp. or self monitoring.mp. or exp self concept/ or behavior modification.mp. or exp cognitive therapy/ or cognitive behavior.mp.
6 and 7
exp "randomized controlled trials"/ or exp single-blind method/ or exp double-blind method/ or exp random allocation/
8 and 9
limit 8 to randomized controlled trial
10 or 11

Behavioral Therapy Reviews

Search History
exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
1 and 2
limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
3 or 4
limit 5 to (human and english language and yr=1980–2003)
exp behavior/ or exp behavior therapy/ or exp goals/ or goal setting.mp. or self monitoring.mp. or exp self concept/ or behavior modification.mp. or exp cognitive therapy/ or cognitive behavior.mp.
6 and 7
limit 8 to review articles
limit 8 to meta analysis
9 or 10

d) Does intentional weight loss lead to improved health? (from 2b; same searches as for Task 5a but looking at health outcomes as available; if needed, refer to USPSTF general population findings)
e) Do behavioral therapies lead to improved health? (evaluate health outcomes from the RCTs in behavioral searches above)

## Task 6 Are there weight loss surgeries that improve net health outcomes in the elderly?

a. Are there surgical therapies that can lead to weight loss?
  Surgical Searches: RCTs
  Search History
  exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
  exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
  1 and 2
  limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
  3 or 4
  limit 5 to (human and english language and yr=1980–2003)
  obesity/su or exp GASTROPLASTY/ or exp Gastric Bypass/ or exp ANASTOMOSIS, ROUX-EN-Y/ or exp ANASTOMOSIS, SURGICAL/ or exp jejunoileal bypass/ or duodenal switch.mp. or exp Biliopancreatic Diversion/ or gastric resection.mp.
  6 and 7
  exp "randomized controlled trials"/ or exp single-blind method/ or exp double-blind method/ or exp random allocation/
  8 and 9
  limit 8 to randomized controlled trial
  10 or 11
  Surgical Searches: Review Articles
  Search History
  exp obesity/ or exp body mass index/ or exp body composition/ or exp skinfold thickness/ or exp weight loss/
  exp aged/ or exp postmenopause/ or exp geriatrics/ or aged.mp. or elderly.mp. or gerontologic.mp. or post-menopausal.mp. or geriatric.mp.
  1 and 2
  limit 1 to ("all aged <65 and over>" or "aged <80 and over>")
  3 or 4
  limit 5 to (human and english language and yr=1980–2003)
  obesity/su or exp GASTROPLASTY/ or exp Gastric Bypass/ or exp ANASTOMOSIS, ROUX-EN-Y/ or exp ANASTOMOSIS, SURGICAL/ or exp jejunoileal bypass/ or duodenal switch.mp. or exp Biliopancreatic Diversion/ or gastric resection.mp.
  6 and 7
  limit 8 to review articles
  limit 8 to meta analysis
  9 or 10
b. Does intentional weight loss lead to improved health outcomes? (as in 2b)
c. Does surgical therapy lead to improved health outcomes (we will review health outcome benefits reported in the trials reviewed for 6a).