# Summary of Evidence Strength Criteria [5]

Study design | Criteria
Systematic reviews | Comprehensiveness of sources/search strategy used Standard appraisal of included studies Validity of conclusions Recency and relevance
Case-control studies | Accurate ascertainment of cases Nonbiased selection of cases/controls with exclusion criteria applied equally to both Response rate Diagnostic testing procedures applied equally to each group Appropriate attention to potential confounding variables
Randomized controlled trials (RCTs) and cohort studies | Initial assembly of comparable groups:; - For RCTs: adequate randomization, including concealment and whether potential confounders were distributed equally among groups; - For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination) Important differential loss to follow-up or overall high loss to follow-up Measurements: equal, reliable, and valid (includes masking of outcome assessment) Clear definition of interventions All important outcomes considered Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs
Diagnostic accuracy studies | Diagnostic test relevant, available for primary care, adequately described Study uses a credible reference standard, performed regardless of test results Reference standard interpreted independently of diagnostic test Handles indeterminate results in a reasonable manner Spectrum of patients included in study Sample size Administration of reliable diagnostic test