# Key Questions and Article Eligibility Criteria

Topic and Key Questions | Eligibility Criteria^*^
A. Validity and Precision of Diagnostic Tests for Obesity; - What is the evidence for validity and precision of the different diagnostic studies in the elderly? | Obesity diagnostic test carried out in an out-patient setting Comparison with gold standard or alternative measures of adiposity Sample mean age (median or mid-point if mean not presented) ≥60 years
B. Health Risks of Obesity in the elderly; - Does obesity entail health risk in the elderly?; - How are the different measures of obesity associated with adverse health outcome incidence?; - What are the characteristics of people for whom there is evidence of health risk associated with body weight? | Prospective cohort studies with absolute or relative rates of health risk reported over at least 10 years of follow-up No systematic body weight intervention Outcome measures (morbidity or mortality) presented according to baseline weight status measures. Sample mean age ≥ 60 years
C. Efficacy and harms of policy-relevant treatment for weight reduction or intermediate outcomes; - Are there dietary, behavioral, or surgical therapies that can lead to weight loss?; - Does intentional weight loss in the elderly lead to improved health outcomes?; - Do dietary, behavioral, or surgical therapies lead to improved health outcomes?; - Do trials assessing weight loss interventions (leading to weight loss or improved health outcomes) address the different measures of adiposity, and if so, show similar outcomes? | Dietary Interventions - RCT (of fair or good quality) - Outcome: weight loss or BMI, WC or WHR reduction - BMI ≥ 25 - Minimum 12 month follow-up - Population: generalizable to typical US primary care population - Sample mean age ≥ 60 years Behavioral Treatment - RCT (of fair or good quality) - Outcome: weight loss or BMI, WC or WHR reduction - BMI ≥ 25 - Minimum 12 month follow-up - Population: generalizable to typical US primary care population - Sample mean age ≥ 60 years Surgical Treatment - RCT (of fair or good quality), or Cohort study with a control group - Surgical procedure currently in clinical use - Outcome: weight loss or BMI reduction - BMI ≥35 - Minimum 12 month follow-up - Initial BMI ≥35 - Sample mean age ≥ 60 years

* RCT, randomized controlled trial; BMI, body mass index; WC, Waist Circumference; WHR, Waist to Hip ratio.