# Executive Summary

## Background

Obesity, a disorder of body composition defined by a relative or absolute excess of body fat, [2] is extremely common among older US adults. In 1999–2000, 33% men and 39% of women aged 65–74 were obese, as were 20% and 25%, respectively, above the age of 74. [1] With steadily increasing prevalence in youth and younger adults, and links with adverse health outcomes, obesity has received increasing clinical and public health attention.

Diagnostic tests for obesity detect either generalized or central fat distribution. Body mass index (BMI = kg. of weight divided by the square of height in meters) is the standard clinical measure of generalized obesity. Skin fold thickness also correlates closely with overall body fat percentage. Waist circumference (WC) and waist-to-hip ratio (WHR) aim to detect central fat accumulation, as it carries increased cardiovascular risk. Accuracy and clinical relevance of these tools varies with gender and ethnicity, and possibly age.

In the general adult population, most treatment options (diet, exercise and behavioral, or pharmacologic) can lead to modest, sustainable improvements in weight, sufficient for improving intermediate health measures such as glycemic control, lipids, and blood pressure. [3–5] [6] Surgical intervention among the very obese can produce substantial weight loss and may markedly improve a number of health outcomes. However, high-quality surgical data are lacking, and while surgical adverse events are rare, they can be serious. [6] As there are age-related differences in fat distribution, physiology, and underlying health status, the generalizability of these findings to older populations is unclear.

## Aim of the Review

To examine the data for the effectiveness of obesity diagnosis and treatment in the elderly, we conducted a systematic review of policy-relevant obesity diagnosis and treatment options in this group.

## Methods

We developed a series of key questions for approaching six policy-pertinent tasks, posed by the Centers for Medicare and Medicaid Services (CMS) and the Agency for Healthcare Research and Quality (AHRQ), regarding obesity diagnosis and treatment in the elderly. We established eligibility criteria for literature inclusion, and rated evidence strength and study internal validity using standard criteria. [7] [8] To capture all data relevant to the aging population in the setting of limited studies, we considered data based on adults aged 60 years or above.

We searched MEDLINE and the Cochrane Library and reviewed bibliographies of published reviews for articles published in English between January 1980 and February 2003 (Appendix 2). At least two authors independently reviewed abstracts and articles, excluded those not meeting eligibility criteria, and abstracted the eligible articles. For topics on which data specific to the elderly were insufficient, we drew from findings of prior systematic reviews in the general population.

## Results

Findings are organized according to the six policy-relevant questions.

### 1 Are there limitations in diagnosing obesity in the elderly with BMI? Should another measurement be used with BMI or in place of BMI for diagnosing obesity in the elderly?

Primary limitations to use of BMI in diagnosing obesity in the elderly include (1) A lower correlation with percentage body fat in the old than in the young, and (2) A weaker association with cardiovascular mortality, as well as several intermediaries of cardiovascular morbidity than measures of central adiposity (WC or WHR).

While the correlation between BMI and body fat percentage drops with age, most data show a reasonable correlation persists. In addition, body fat percentage is generally more closely correlated with BMI or WC than other common obesity diagnostic tests in the elderly. Likewise, BMI is the diagnostic measure linked with the broadest range of subsequent health states. Some of these outcomes (e.g., incident functional disability) [9] have not been evaluated by WHR or WC; others (e.g., hip fracture incidence in women) [10] are linked with BMI, but not with WHR or WC (likely reflecting that generalized, not central, obesity is important in their etiology). In addition, among the elderly, weight loss intervention efficacy trials have established that BMI changes with successful intervention; the ability to alter central measures of adiposity is unknown.

To best capture health risk in the aged, BMI should be combined with a measure of central adiposity. Data are inconsistent regarding the relative value of choosing WC versus WHR in the older population, however, WC is easier to measure.

### 2 Can intentional weight loss be used as a surrogate for improved net health outcomes? If so, how much weight loss and over what time period?

In the elderly, intentional weight loss is a reasonable surrogate for certain improvements in health outcomes. Evidence comes from consideration of (1) the health states for which older obese people are at increased risk, and (2) RCT evidence that such risk can be altered with intervention. Based on long term cohort evidence, the obese elderly have increased risk of several cardiovascular-related adverse outcomes (mortality, morbidity, and incidence of intermediary outcomes). In addition, multifaceted counseling-based weight loss interventions (combining dietary, exercise, and behavioral components) can improve cardiovascular intermediaries, including fasting glucose tolerance, diabetes incidence, and a combined cardiovascular intermediary endpoint in generally healthy adults, compared with control participants. Modest weight loss (2 to 3 kg.), sustained over one to three years, was sufficient to produce these clinically meaningful results.

Intentional weight loss in the elderly has an unclear role in altering other obesity-related health risks. Observational data show increased cancer incidence, but not mortality, in older women (data are lacking for men) with increasing body size. However, the ability of intervention to alter this risk is uncertain: weight loss RCTs have limited duration of follow-up, and generally do not assess cancer or its intermediary outcomes. Similarly, while intentional weight loss may be a marker for improved function (cohort data indicate functional limitation increases with obesity), current RCTs in the elderly have not assessed this endpoint.

Longitudinal data linking higher BMI with lower incidence of and mortality from hip fracture in the elderly, coupled with RCT evidence of declining bone mineral density with weight loss interventions, indicate that intentional weight loss has adverse bone effects in older individuals. Obese individuals, though, are at a lower risk of osteoporosis than those with lower body weight. [11]

### 3 Which elderly patients with obesity would experience an improved health outcome with weight loss treatment?

We approached this question by reviewing the characteristics of people with evidence of obesity-associated health problems (cardiovascular disorders, cancer, or functional decline), and those with RCT evidence for health benefit (improved cardiovascular intermediaries) or harms (bone loss) from intentional weight loss.

Those at risk for obesity-associated health problems stand to benefit most from intervention, if such intervention alters their weight-related risk. The strongest evidence for obesity intervention is for those with cardiovascular risk. Cardiovascular risk factors – including family history, diabetes, tobacco use, or dyslipidemia – can help identify this group. Risk for cancer or functional limitation is more complicated and often requires individualized patient assessment. However, several cancers with obesity-linked incidence (e.g., breast, colon) do have clear, identifiable risk factors. Finally, osteopenia, osteoporosis, or its risk factors may help identify those with risk of fracture – e.g., those most likely to experience harm from purposeful weight loss.

Among the elderly, the all-cause mortality risk associated with obesity (and therefore, potential benefit) diminishes with age. While risk of all-cause mortality with obesity is much diminished or absent by age 75 (age 85 in one large group of men), alterations in disease-specific mortality or morbidity risk are largely unknown. In addition, RCT evidence for clinical benefits with weight loss is based on a select sample, including reasonable gender and racial diversity, but lacking ethnic diversity. Trials focused on patients who were moderately overweight to mildly (stage I) obese and generally lacked substantial co-morbidities. It is unclear how these findings are generalized beyond this group.

### 4 Are there dietary or behavioral therapies that improve net health outcomes in obese elderly?

Obesity therapies with good evidence for improving health outcomes in the elderly incorporate both dietary and behavioral components; therefore, we consider these modes jointly here. All successful studies included exercise and used intensive counseling protocols. Effective interventions typically used diets based on reduced caloric intake, [12] often in the setting of low-saturated-fat and low-cholesterol intake goals. [13] Average weight loss was slightly less than found in younger samples (2–3 kg. versus 3–5 kg.); this may reflect the limited number of studies. Weight loss showed clinical utility, particularly for cardiovascular-related benefits such as oral glucose tolerance testing or diabetes incidence. [13, 14] One intervention promoted a 71% reduction in diabetes incidence over placebo among glucose-intolerant elders (versus a corresponding reduction of 59% among those aged 45–59 years). In another trial, intervention participants showed a 30% reduction in a combined cardiovascular endpoint (persistently elevated blood pressure, re-initiation of antihypertensive medication, or a major blood pressure related clinical complication such as a cardiovascular event or surgery). [12] [15] While weight loss intervention efficacy data are very limited in the elderly, findings are consistent with the much larger body of literature focusing on younger adults. [6] The addition of long-term weight maintenance strategies helps to sustain weight loss in younger groups, but has not been evaluated among the aged. Although we did not specifically evaluate physical activity, it is important to note that both successful weight loss programs included a physical activity component. [13] [12] Also, incorporating exercise into weight dietary interventions may reduce the risk of bone loss. [16]

### 5 Are there surgical therapies that improve net health outcomes in obese elderly?

Current data are insufficient to assess the efficacy or safety of bariatric surgery in the elderly. We identified no RCTs evaluating surgical obesity treatment in the aged population. In the younger population, surgery can promote large degrees of weight loss among those with extreme obesity. [6] Its’ complications are infrequent, but can be severe, including death. As chronic illness increases with age, and both age and co-morbidity have been linked with peri-operative risk, surgical adverse outcome rates based on younger populations may not generalize to the elderly.

## Limitations

The primary limitation in these analyses is the lack of data specific to the elderly. Diagnostic testing studies were primarily limited by few calculated testing parameters (e.g., sensitivity, specificity, and predictive values). Longitudinal studies often did not stratify findings by age or report attrition rates; also, statistical approaches frequently were inappropriate for our question. Dietary intervention studies showed high attrition rates, and sometimes, insufficient adjustment for potential confounders. Longitudinal studies had minimal racial diversity, and overall, the literature examined samples with limited age, ethnicity, and baseline weight status, potentially limiting generalizability of findings.

## Conclusions

BMI is an adequate measure of body fat percentage in the elderly. WC and WHR provide additional information, particularly for identifying people at high cardiovascular risk. Skinfold thickness is a less desirable measure.

While, currently, there are no data directly measuring the effect that weight loss intervention has on mortality, intentional weight loss can serve as a valid marker for certain improved cardiovascular-related endpoints. Diabetes and blood pressure control are also important health problems, independent of their link to cardiovascular disease. [1] Possibly, additional benefits may be realized regarding cancer and functional disability. However, weight loss is also linked with adverse bone-related consequences.

The obese elderly most likely to benefit from weight loss are those with cardiovascular-related disease, or at high risk for these disorders. Those with high risk of cancer or functional decline may benefit as well. However, slowly developing disease processes and lack of reliable disease intermediaries makes evidence for cancer benefit difficult to establish. Intentional weight loss should be pursued with caution in the elderly with high osteoporosis risk. Among those with mixed risk patterns (e.g., cardiovascular and bone-related risk), relative benefits versus harms can only be individually assessed.

Overall, these findings reflect data from relatively healthy men and women; while race-specific data are limited, black participants’ cardiovascular-related benefit from intentional weight loss appears similar to that of white participants. Modulation by ethnicity or underlying health status is unclear. As the relationship between all-cause mortality risk and obesity recedes with age and is absent after about age 74, any potential all-cause mortality benefit of weight loss programs likely diminishes as well. The relationship between morbidity or disease-specific mortality and obesity has not been assessed for age-related change in older adults.

Dietary interventions can promote clinically significant weight loss (2–3 kg.) in the aged over 1–3 years. Data reflect low calorie, often relatively low-fat diets, delivered with behavioral theory approaches. While we did not evaluate physical activity as an independent approach to obesity in the elderly, all successful dietary interventions included physical activity components, and physical activity may help offset the risk of bone loss found with intentional weight loss programs. These conclusions are based on efficacy (rather than effectiveness) data. Minimal data assessed harms of such counseling-based treatment. Data are insufficient to assess the safety or efficacy of bariatric surgery in the obese elderly.