# References

1 U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. Health, United States, 2002 (updated trend table 10/8/2002). Hyattsville, MD. National Center for Health Statistics. 2002.
2 Hellerstein M, Parks E. Greenspan F, Gardner D, editors. Obesity and Overweight, in Basic and Clinical Endocrinology. MCGraw-Hill. 2001:745.
3 National Obesity Education Initiative. Clinical guidelines on the identification, evaluation and treatment of overweight and obesity in adults: the Evidence Report. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Heart, Lung and Blood Institute. Bethesda, MD. 1998.
4 Douketis JD, et al. Periodic health examination, 1999 update: 1. Detection, prevention and treatment of obesity. Canadian Task Force on Preventive Health Care. Cmaj. 1999;160(4):513-525. [pmid: 10081468].
5 US Preventive Services Task Force. Guide to Clinical Preventive Services. 2 ed. Alexandria, Virginia. International Medical Publishing, Inc. 1996:219-229.
6 McTigue KM, et al. Screening and Interventions for Obesity in Adults: Summary of the Evidence for the U.S. Preventive Services Task Force. Annals of Internal Medicine. in press.
7 Harris RP, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
8 Jaeschke R, Guyatt G, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. A. Are the results of the study valid? Evidence-Based Medicine Working Group. Jama. 1994;271(5):389-391. [pmid: 8283589].
9 Launer LJ, et al. Body mass index, weight change, and risk of mobility disability in middle-aged and older women. The epidemiologic follow-up study of NHANES I. Jama. 1994;271(14):1093-1098. [pmid: 8151851].
10 Folsom AR, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Archives of Internal Medicine. 2000;160(14):2117-2128. [pmid: 10904454].
11 Ribot, C., Tremollieres F, Pouilles JM. The effect of obesity on postmenopausal bone loss and the risk of osteoporosis. Adv Nutr Res. 1994;9:257-271. [pmid: 7747670].
12 Appel LJ, et al. Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Annals of Epidemiology. 1995;5(2):119-29. [pmid: 7795830].
13 Knowler WC, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. New England Journal of Medicine. 2002;46(6):393-403. [pmid: 11832527].
14 Fagerberg B, et al. Multifactorial treatment of hypertensive men at high cardiovascular risk and low-density lipoprotein cholesterol affinity to human arterial proteoglycans. European Journal of Clinical Investigation. 1996;26(11):960-965. [pmid: 8957200].
15 Whelton PK, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group.[comment][erratum appears in JAMA 1998 Jun 24;279 (24):1954]. Jama. 1998;279(11):839-846. [pmid: 9515998].
16 Ernst E, et al. Exercise for female osteoporosis. A systematic review of randomised clinical trials. Sports Med. 1998;25(6):359-68. [pmid: 9680658].
17 Strauss RS, Pollack HA. Epidemic increase in childhood overweight, 1986–1998. Jama. 2001;286(22):2845-2848. [pmid: 11735760].
18 U. S. Department of Health and Human Services, C.f.D.C.a.P. The Surgeon General's call to action to prevent and decrease overweight and obesity. Rockville, Maryland. U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General. 2001.
19 Rexrode KM, et al. Abdominal adiposity and coronary heart disease in women. Jama. 1998;280(21):1843-1848. [pmid: 9846779].
20 Liese AD, et al. Development of the multiple metabolic syndrome in the ARIC cohort: joint contribution of insulin, BMI, and WHR. Atherosclerosis risk in communities. Ann Epidemiol. 1997;7(6):407-416. [pmid: 9279450].
21 Baik I, et al. Adiposity and mortality in men. Am J Epidemiol. 2000;152(3):264-271. [pmid: 10933273].
22 Janssen I, Katzmarzyk PT, Ross R. Body mass index, waist circumference, and health risk: evidence in support of current National Institutes of Health guidelines. Arch Intern Med. 2002;162(18):2074-2079. [pmid: 12374515].
23 Lovejoy JC, et al. Abdominal fat distribution and metabolic risk factors: effects of race. Metabolism. 1996;45(9):1119-1124. [pmid: 8781299].
24 Albu JB, et al. Visceral fat and race-dependent health risks in obese nondiabetic premenopausal women. Diabetes. 1997;46(3):456-462. [pmid: 9032103].
25 Casas YG, et al. Total and regional body composition across age in healthy Hispanic and white women of similar socioeconomic status. Am J Clin Nutr. 2001;73(1):13-18. [pmid: 11124743].
26 Dowling HJ, Pi-Sunyer FX. Race-dependent health risks of upper body obesity. Diabetes. 1993;42(4):537-543. [pmid: 8454103].
27 Conway JM, et al. Visceral adipose tissue differences in black and white women. Am J Clin Nutr. 1995;61(4):765-771. [pmid: 7702017].
28 Lear SA, et al. The relationship between waist circumference and metabolic risk factors: cohorts of European and Chinese descent. Metabolism. 2002;51(11):1427-1432. [pmid: 12404193].
29 Wajchenberg BL. Subcutaneous and visceral adipose tissue: their relation to the metabolic syndrome. Endocr Rev. 2000;21(6):697-738. [pmid: 11133069].
30 Park YW, et al. Larger amounts of visceral adipose tissue in Asian Americans. Obes Res. 2001;9(7):381-387. [pmid: 11445659].
31 Hill JO, et al. Racial differences in amounts of visceral adipose tissue in young adults: the CARDIA (Coronary Artery Risk Development in Young Adults) study. Am J Clin Nutr. 1999;69(3):381-387. [pmid: 10075320].
32 Bacha F, et al. Obesity, regional fat distribution, and syndrome X in obese black versus white adolescents: race differential in diabetogenic and atherogenic risk factors. J Clin Endocrinol Metab. 2003;88(6):2534-2540. [pmid: 12788850].
33 Visser M, et al. One- and two-year change in body composition as measured by DXA in a population-based cohort of older men and women. J Appl Physiol. 2003;94(6):2368-2374. [pmid: 12598481].
34 Elia M. Obesity in the elderly. Obesity Research. Suppl 4. 2001;9:244S-248S. [pmid: 11707549].
35 Logue E, Smucker WD, Bourguet CC. Identification of obesity: waistlines or weight? Nutrition, Exercise, and Obesity Research Group. Journal of Family Practice. 1995;41(4):357-363. [pmid: 7561709].
36 Steen B. Body composition and aging. Nutrition Reviews. 1988;46(2):45-51. [pmid: 3279343].
37 Prevalence of Diabetes and Impaired Fasting Glucose in Adults - United Sttes, 1999–2000. MMWR Morb Mortal Wkly Rep. 2003;52(35):833-837. [pmid: 12966357].
38 Campbell VA, et al. Surveillance for sensory impairment, activity limitation, and health-related quality of life among older adults--United States, 1993–1997. MMWR CDC Surveill Summ. 1999;48(8):131-156. [pmid: 10634273].
39 Prevalence of disabilities and associated health conditions among adults--United States, 1999. MMWR Morb Mortal Wkly Rep. 2001;50(7):120-155. [pmid: 11393491].
40 Public health and aging: projected prevalence of self-reported arthritis or chronic joint symptoms among persons aged >65 years--United States, 2005–2030. MMWR Morb Mortal Wkly Rep. 2003;52(21):489-491. [pmid: 12809109].
41 Barrett JA, et al. Fracture risk in the U.S. Medicare population. J Clin Epidemiol. 1999;52(3):243-249. [pmid: 10210242].
42 Ensrud KE, et al. Correlates of impaired function in older women. J Am Geriatr Soc. 1994;42(5):481-9. [pmid: 8176141].
43 Jensen GL, Friedmann JM. Obesity is associated with functional decline in community-dwelling rural older persons. Journal of the American Geriatrics Society. 2002;50(5):918-923. [pmid: 12028181].
44 Jordan JM, et al. Self-reported functional status in osteoarthritis of the knee in a rural southern community: the role of sociodemographic factors, obesity, and knee pain. Arthritis Care Res. 1996;9(4):273-8. [pmid: 8997916].
45 Wolf AM, Colditz GA. Current estimates of the economic cost of obesity in the United States. Obes Res. 1998;6(2):97-106. [pmid: 9545015].
46 Thompson D, et al. Lifetime health and economic consequences of obesity. Arch Intern Med. 1999;159(18):2177-83. [pmid: 10527295].
47 Harris TB, et al. Cohort study of effect of being overweight and change in weight on risk of coronary heart disease in old age. Bmj. 1997;314(7097):1791-1794. [pmid: 9224080].
48 Somes GW, et al. Body mass index, weight change, and death in older adults: the systolic hypertension in the elderly program. Am J Epidemiol. 2002;156(2):132-8. [pmid: 12117704].
49 Reynolds MW, et al. Weight, weight change, mortality in a random sample of older community-dwelling women.[comment]. Journal of the American Geriatrics Society. 1999;47(12):1409-14. [pmid: 10591233].
50 Wedick NM, et al. The relationship between weight loss and all-cause mortality in older men and women with and without diabetes mellitus: the Rancho Bernardo study. Journal of the American Geriatrics Society. 2002;50(11):1810-5. [pmid: 12410899].
51 Newman AB, et al. Weight change in old age and its association with mortality. J Am Geriatr Soc. 2001;49(10):1309-18. [pmid: 11890489].
52 Wallace JI, Schwartz RS. Epidemiology of weight loss in humans with special reference to wasting in the elderly. Int J Cardiol. 2002;85(1):15-21. [pmid: 12163206].
53 French SA, et al. Prospective study of intentionality of weight loss and mortality in older women: the Iowa Women's Health Study. Am J Epidemiol. 1999;149(6):504-14. [pmid: 10084239].
54 NHS Centre for Reviews and Dissemination, U.o.Y. The prevention and treatment of obesity. Eff Health Care. 1997;97(3):1-12.
55 Sheridan S, Pignone M, Donahue K. Screening for high blood pressure: a review of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2003;25(2):151-158. [pmid: 12880884].
56 Harris R, et al. Screening adults for type 2 diabetes: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;138(3):215-229. [pmid: 12558362].
57 Clegg AJ, et al. The clinical effectiveness and cost-effectiveness of surgery for people with morbid obesity: a systematic review and economic evaluation. Health Technology Assessment. 2002;6(12).
58 Whitlock EP, et al. Evaluating primary care behavioral counseling interventions: an evidence-based approach. Am J Prev Med. 2002;22(4):267-284. [pmid: 11988383].
59 Deurenberg P, Weststrate JA, Seidell JC. Body mass index as a measure of body fatness: age- and sex-specific prediction formulas. Br J Nutr. 1991;65(2):105-114. [pmid: 2043597].
60 Goodman-Gruen D, Barrett-Connor E. Sex differences in measures of body fat and body distribution in the elderly. American Journal of Epidemiology. 1996;143(9):898-906. [pmid: 8610703].
61 Ko GT, et al. Lower BMI cut-off value to define obesity in Hong Kong Chinese: an analysis based on body fat assessment by bioelectrical impedance.[comment]. British Journal of Nutrition. 2001;85(2):239-242. [pmid: 11242492].
62 Molarius A, et al. Misclassification of high-risk older subjects using waist action levels established for young and middle-aged adults--results from the Rotterdam Study. Journal of the American Geriatrics Society. 2000;48(12):1638-1645. [pmid: 11129755].
63 Okosun IS, et al. Abdominal adiposity values associated with established body mass indexes in white, black and hispanic Americans. A study from the Third National Health and Nutrition Examination Survey. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2000;24(10):1279-1285.
64 Olson JE, et al. Differential association of body mass index and fat distribution with three major histologic types of lung cancer: evidence from a cohort of older women. American Journal of Epidemiology. 2002;156(7):606-615. [pmid: 12244029].
65 Bussolotto M, et al. Assessment of body composition in elderly: accuracy of bioelectrical impedance analysis. Gerontology. 1999;45(1):39-43. [pmid: 9852379].
66 Abbott RD, et al. Body mass index and thromboembolic stroke in nonsmoking men in older middle age. The Honolulu Heart Program. Stroke. 1994;25(12):2370-2376. [pmid: 7974575].
67 Baik I, et al. Adiposity and mortality in men. American Journal of Epidemiology. 2000;152(3):264-271. [pmid: 10933273].
68 Calle EE, et al. Body-mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341(15):1097-1105. [pmid: 10511607].
69 Cerhan JR, et al. Association of smoking, body mass, and physical activity with risk of prostate cancer in the Iowa 65+ Rural Health Study (United States). Cancer Causes & Control. 1997;8(2):229-238. [pmid: 9134247].
70 Cornoni-Huntley JC, et al. An overview of body weight of older persons, including the impact on mortality. The National Health and Nutrition Examination Survey I--Epidemiologic Follow-up Study. Journal of Clinical Epidemiology. 1991;44(8):743-753. [pmid: 1941025].
71 Dey DK, et al. Waist circumference, body mass index, and risk for stroke in older people: a 15 year longitudinal population study of 70- year-olds. Journal of the American Geriatrics Society. 2002;50(9):1510-1518. [pmid: 12383148].
72 Dey DK, et al. Body mass index, weight change and mortality in the elderly. A 15 y longitudinal population study of 70 y olds. European Journal of Clinical Nutrition. 2001;55(6):482-492. [pmid: 11423925].
73 Dorn JM, et al. Body mass index and mortality in a general population sample of men and women. The Buffalo Health Study. American Journal of Epidemiology. 1997;146(11):919-931. [pmid: 9400333].
74 Ellekjaer H, Holmen J, Vatten L. Blood pressure, smoking and body mass in relation to mortality from stroke and coronary heart disease in the elderly. A 10-year follow-up in Norway. Blood Pressure. 2001;10(3):156-163. [pmid: 11688763].
75 Fitzgerald AP, Jarrett RJ. Body weight and coronary heart disease mortality: an analysis in relation to age and smoking habit. 15 years follow-up data from the Whitehall Study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 1992;16(2):119-123.
76 Heitmann BL, et al. Mortality associated with body fat, fat-free mass and body mass index among 60-year-old swedish men-a 22-year follow-up. The study of men born in 1913. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2000;24(1):33-37.
77 Mazza A, et al. Cancer mortality trends in two cohorts of elderly people having different life-styles. Aging-Clinical & Experimental Research. 1999;11(1):21-29.
78 Singh PN, Lindsted KD. Body mass and 26-year risk of mortality from specific diseases among women who never smoked.[comment]. Epidemiology. 1998;9(3):246-254. [pmid: 9583415].
79 Singh PN, Lindsted KD, Fraser GE. Body weight and mortality among adults who never smoked. American Journal of Epidemiology. 1999;150(11):1152-1164. [pmid: 10588076].
80 Stevens J, et al. The effect of age on the association between body-mass index and mortality. N Engl J Med. 1998;338(1):1-7. [pmid: 9414324].
81 Heiat A, Vaccarino V, Krumholz HM. An evidence-based assessment of federal guidelines for overweight and obesity as they apply to elderly persons. Arch Intern Med. 2001;161(9):1194-1203. [pmid: 11343442].
82 Shinton R, Shipley M, Rose G. Overweight and stroke in the Whitehall study. Journal of Epidemiology & Community Health. 1991;45(2):138-142. [pmid: 2072073].
83 Meyer HE, Tverdal A, Falch JA. Body height, body mass index, and fatal hip fractures: 16 years' follow-up of 674,000 Norwegian women and men. Epidemiology. 1995;6(3):299-305. [pmid: 7619940].
84 Cerhan JR, et al. Anthropometric characteristics, physical activity, and risk of non-Hodgkin's lymphoma subtypes and B-cell chronic lymphocytic leukemia: a prospective study. American Journal of Epidemiology. 2002;156(6):527-535. [pmid: 12226000].
85 Allen JK. Coronary risk factor modification in women after coronary artery bypass surgery. Nursing Research. 1996;45(5):260-265. [pmid: 8831651].
86 Chao D, et al. Effect of voluntary weight loss on bone mineral density in older overweight women. Journal of the American Geriatrics Society. 2000;48(7):753-759. [pmid: 10894313].
87 Deurenberg-Yap M, et al. The paradox of low body mass index and high body fat percentage among Chinese, Malays and Indians in Singapore. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2000;24(8):1011-1017.
88 Takala JK, Mattila KJ, Ryynanen OP. Overweight, underweight and mortality among the aged. Scandinavian Journal of Primary Health Care. 1994;12(4):244-248. [pmid: 7863141].
89 Kumanyika SK, et al. Ethnic comparison of weight loss in the Trial of Nonpharmacologic Interventions in the Elderly. Obesity Research. 2002;10(2):96-106. [pmid: 11836455].
90 Kostis JB, et al. Persistence of normotension after discontinuation of lifestyle intervention in the trial of TONE. Trial of Nonpharmacologic Interventions in the Elderly. Am J Hypertens. 2002;15(8):732-734. [pmid: 12160197].
91 De Laet CE, et al. Hip fracture prediction in elderly men and women: validation in the Rotterdam study. J Bone Miner Res. 1998;13(10):1587-1593. [pmid: 9783547].
92 Gastrointestinal Surgery for Severe Obesity. NIH Concens Statement Online. 1991.
93 McTigue KM, et al. Screening and Interventions for Obesity in Adults: Summary of the Evidence for the U.S. Preventive Services Task Force. in review.
94 Fleisher LA, Eagle KA. Screening for cardiac disease in patients having noncardiac surgery. Ann Intern Med. 1996;124(8):767-772. [pmid: 8633839].
95 Goldman L, et al. Multifactorial index of cardiac risk in noncardiac surgical procedures. N Engl J Med. 1977;297(16):845-850. [pmid: 904659].
96 Goldman L, et al. Cardiac risks and complications of noncardiac surgery. Ann Intern Med. 1983;98(4):504-513. [pmid: 6340579].
97 Berg AO. U.S. Preventive services task force. Behavioral counseling in primary care to promote physical activity: recommendation and rationale. Am J Nurs. 2003;103(4):101-107. discussion 109. [pmid: 12677132].
98 Stevens J, et al. Fitness and fatness as predictors of mortality from all causes and from cardiovascular disease in men and women in the lipid research clinics study. Am J Epidemiol. 2002;156(9):832-841. [pmid: 12397001].