# Bibliography

Albers P, Bender H, Yilmaz H, et al. Positron emission tomography in the clinical staging of patients with Stage I and II testicular germ cell tumors. Urology. 1999;53(4):808-11. [pmid: 10197862].
Albers P, Ulbright TM, Albers J, et al. Tumor proliferative activity is predictive of pathological stage in clinical stage A nonseminomatous testicular germ cell tumors. Journal of Urology. 1996;155(2):579-86. [pmid: 8558664].
American Cancer Society. Cancer Facts and Figures 2002. http://www.cancer.org/docroot/STT/stt_0_2002.asp?sitearea=STT&level=1. 2002.
American Cancer Society. Cancer Facts and Figures. 2003. Available at http://www.cancer.org/docroot/STT/stt_0.asp. Accessed November 18, 2003.
Bader JB, Samnick S, Moringlane JR, et al. Evaluation of l-3-[123I]iodo-alpha-methyltyrosine SPET and [18F]fluorodeoxyglucose PET in the detection and grading of recurrences in patients pretreated for gliomas at follow-up: a comparative study with stereotactic biopsy. European Journal of Nuclear Medicine. 1999;26(2):144-51. [pmid: 9933348].
Bares R, Klever P, Hauptmann S, et al. F-18 fluorodeoxyglucose PET in vivo evaluation of pancreatic glucose metabolism for detection of pancreatic cancer. Radiology. 1994;192(1):79-86. [pmid: 8208970].
Bares R, Klever P, Hellwig D, et al. Pancreatic cancer detected by positron emission tomography with 18F-labelled deoxyglucose: method and first results. Nuclear Medicine Communications. 1993;14(7):596-601. [pmid: 8355920].
Barker FG 2nd, Chang SM, Valk PE, et al. 18-Fluorodeoxyglucose uptake and survival of patients with suspected recurrent malignant glioma. Cancer. 1997;79(1):115-26. [pmid: 8988735].
Bast RC Jr, Klug TL, St John E, Jenison E, Niloff JM, Lazarus H, Berkowitz RS, Leavitt T, Griffiths CT, Parker L, Zurawski VR Jr, Knapp RC. A radioimmunoassay using a monoclonal antibody to monitor the course of epithelial ovarian cancer. New England Journal of Medicine. Oct. 13. 1983;309(15):883-7. [pmid: 6310399].
Belhocine T, Thille A, Fridman V, et al. Contribution of whole-body 18FDG PET imaging in the management of cervical cancer. Gynecologic Oncology. 2002;87(1):90-7. [pmid: 12468348].
Bolis G, Colombo N, Pecorelli S, Torri V, Marsoni S, Bonazzi C, Chiari S, Favalli G, Mangili G, Presti M, et al. Adjuvant treatment for early epithelial ovarian cancer: results of two randomised clinical trials comparing cisplatin to no further treatment or chromic phosphate (32P). G.I.C.O.G.: Gruppo Interregionale Collaborativo in Ginecologia Oncologica. Ann Oncol. Nov. 1995;6(9):887-93. [pmid: 8624291].
Bristow RE, Montz FJ, Lagasse LD, Leuchter RS, Karlan BY. Survival impact of surgical cytoreduction in stage IV epithelial ovarian cancer. Gynecol Oncol. Mar. 1999;72(3):278-87. [pmid: 10053096].
Buist MR, Golding RP, Burger CW, Vermorken JB, Kenemans P, Schutter EM, Baak JP, Heitbrink MA, Falke TH. Comparative evaluation of diagnostic methods in ovarian carcinoma with emphasis on CT and MRI. Gynecol Oncol. Feb. 1994;52(2):191-8. [pmid: 8314138].
Bunn PA, Carney DN. Overview of chemotherapy for small cell lung cancer. Semin Oncol. 1997;24(S7):69-74.
Canney PA, Moore M, Wilkinson PM, James RD. Ovarian cancer antigen CA125: a prospective clinical assessment of its role as a tumour marker. Br J Cancer. Dec. 1984;50(6):765-9. [pmid: 6208925].
Central Brain Tumor Registry of the United States. Statistical Table 8. http://www.cbtrus.org/2002/table2002_8.htm. 2002.
Chang WC, Hung YC, Kao CH, et al. Usefulness of whole body positron emission tomography (PET) with 18F-fluoro-2-deoxyglucose (FDG) to detect recurrent ovarian cancer based on asymptomatically elevated serum levels of tumor marker. Neoplasma. 2002;49(5):329-33. [pmid: 12458332].
Chin R Jr, McCain TW, Miller AA, et al. Whole body FDG-PET for the evaluation and staging of small cell lung cancer: a preliminary study. [comment]. Lung Cancer. 2002;37(1):1-6. [pmid: 12057859].
Chin R, Ward R, Keyes JW, et al. Mediastinal staging of non-small-cell lung cancer with positron emission tomography. Am J Respri Crit Care Med. 1995;152:2090-6.
Cho SM, Ha HK, Byun JY, et al. Usefulness of FDG PET for assessment of early recurrent epithelial ovarian cancer. AJR. American Journal of Roentgenology. 2002;179(2):391-5. [pmid: 12130439].
Clark R, Ihde DC. Small-cell lung cancer: treatment progress and prospects. Oncology. 1998;12:647-58. [pmid: 9597676].
Clarke-Pearson DL, Bandy LC, Dudzinski M, Heaston D, Creasman WT. Computed tomography in evaluation of patients with ovarian carcinoma in complete clinical remission. Correlation with surgical-pathologic findings. JAMA. Feb. 7. 1986;255(5):627-30. [pmid: 3944963].
Cremerius U, Effert PJ, Adam G, et al. FDG PET for detection and therapy control of metastatic germ cell tumor. Journal of Nuclear Medicine. 1998;39(5):815-22. [pmid: 9591582].
Cremerius U, Wildberger JE, Borchers H, et al. Does positron emission tomography using 18-fluoro-2-deoxyglucose improve clinical staging of testicular cancer?--Results of a study in 50 patients. Urology. 1999;54(5):900-4. [pmid: 10565755].
Curtin JP, Malik R, Venkatraman ES, Barakat RR, Hoskins WJ. Stage IV ovarian cancer: impact of surgical debulking. Gynecol Oncol. Jan. 1997;64(1):9-12. [pmid: 8995540].
De Santis M, Bokemeyer C, Becherer A, et al. Predictive impact of 2-18fluoro-2-deoxy-D-glucose positron emission tomography for residual postchemotherapy masses in patients with bulky seminoma. [erratum appears in J Clin Oncol 2001 Dec 1;19(23):4355]. Journal of Clinical Oncology. 2001;19(17):3740-4. [pmid: 11533096].
De Witte O, Lefranc F, Levivier M, et al. FDG-PET as a prognostic factor in high-grade astrocytoma. Journal of Neuro-Oncology. 2000;49(2):157-63. [pmid: 11206011].
Delbeke D, Meyerowitz C, Lapidus RL, et al. Optimal cutoff levels of F-18 fluorodeoxyglucose uptake in the differentiation of low-grade from high-grade brain tumors with PET. Radiology. 1995;195(1):47-52. [pmid: 7892494].
Delbeke D, Rose DM, Chapman WC, et al. Optimal interpretation of FDG PET in the diagnosis, staging and management of pancreatic carcinoma. Journal of Nuclear Medicine. 1999;40(11):1784-91. [pmid: 10565771].
Deshmukh A, Scott JA, Palmer EL, et al. Impact of fluorodeoxyglucose positron emission tomography on the clinical management of patients with glioma. Clinical Nuclear Medicine. 1996;21(9):720-5. [pmid: 8879874].
Diederichs CG, Staib L, Vogel J, et al. Values and limitations of 18F-fluorodeoxyglucose-positron-emission tomography with preoperative evaluation of patients with pancreatic masses. Pancreas. 2000;20(2):109-16. [pmid: 10707924].
Evans DB, Abbruzzese JL, Rish TA. Cancer of the pancreas. DeVita VT, Hellman S, Rosenberg SA, editors. Cancer: Principles and Practice of Oncology. ed 5. Philadelphia, PA. Lippincott-Raven. 1997.
Executive Committee Working Group. Centers for Medicare and Medicaid Services Website. http://cms.hhs.gov/coverage/8b1-i9.asp. 2001.
Fernandez EB, Moul JW, Foley JP, et al. Retroperitoneal imaging with third and fourth generation computed axial tomography in clinical stage I nonseminomatous germ cell tumors. Urology. Oct. 1994;44(4):548-52. Review. [pmid: 7941194].
Friess H, Langhans J, Ebert M, et al. Diagnosis of pancreatic cancer by 2[18F]-fluoro-2-deoxy-D-glucose positron emission tomography. [erratum appears in Gut 1995 Sep;37(3):448]. Gut. 1995;36(5):771-7. [pmid: 7797130].
Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Medical Decision Making. 1991;11(2):88-94. [pmid: 1907710].
Ganjoo KN, Chan RJ, Sharma M, et al. Positron emission tomography scans in the evaluation of postchemotherapy residual masses in patients with seminoma. Journal of Clinical Oncology. 1999;17(11):3457-60. [pmid: 10550142].
Greenlee RT, Hill-Harmon MB, Murray T, et al. Cancer Statistics, 2001. CA Cancer J Clin. 2001;51:15-36. [pmid: 11577478].
Grigsby PW, Siegel BA, Dehdashti F. Lymph node staging by positron emission tomography in patients with carcinoma of the cervix. Journal of Clinical Oncology. 2001;19(17):3745-9. [pmid: 11533097].
Grigsby PW, Siegel BA, Dehdashti F, et al. Posttherapy surveillance monitoring of cervical cancer by FDG-PET. International Journal of Radiation Oncology, Biology, Physics. 2003;55(4):907-13.
Hain SF, O'Doherty MJ, Timothy AR, et al. Fluorodeoxyglucose PET in the initial staging of germ cell tumours. European Journal of Nuclear Medicine. 2000;27(5):590-4. [pmid: 10853816].
Hain SF, O'Doherty MJ, Timothy AR, Leslie MD, Harper PG, Huddart RA. Fluorodeoxyglucose positron emission tomography in the evaluation of germ cell tumours at relapse. Br J Cancer. 2000;83:863-869. [pmid: 10970686].
Hawkins RE, Roberts K, Wiltshaw E, Mundy J, McCready VR. The clinical correlates of serum CA125 in 169 patients with epithelial ovarian carcinoma. Br J Cancer. Oct. 1989;60(4):634-7. [pmid: 2803938].
Ho CL, Dehdashti F, Griffeth LK, et al. FDG-PET evaluation of indeterminate pancreatic masses. Journal of Computer Assisted Tomography. 1996;20(3):363-9. [pmid: 8626891].
Horwich A, Alsanjari N, A’Hern R, et al. Surveillance following orchidectomy for stage I testicular seminoma. Br J Cancer. May. 1992;65(5):775-8. [pmid: 1586607].
Hoskins WJ, McGuire WP, Brady MF, Homesley HD, Creasman WT, Berman M, Ball H, Berek JS. The effect of diameter of largest residual disease on survival after primary cytoreductive surgery in patients with suboptimal residual epithelial ovarian carcinoma. American Journal of Obstetrics and Gynecology. Apr. 1994;170(4):974-9. discussion 979–80. [pmid: 8166218].
Hubner KF, McDonald TW, Niethammer JG, et al. Assessment of primary and metastatic ovarian cancer by positron emission tomography (PET) using 2-[18F]deoxyglucose (2-[18F]FDG). Gynecologic Oncology. 1993;51(2):197-204. [pmid: 8276294].
Imdahl A, Nitzsche E, Krautmann F, et al. Evaluation of positron emission tomography with 2-[18F]fluoro-2-deoxy-D-glucose for the differentiation of chronic pancreatitis and pancreatic cancer. British Journal of Surgery. 1999;86(2):194-9. [pmid: 10100786].
Inokuma T, Tamaki N, Torizuka T, et al. Evaluation of pancreatic tumors with positron emission tomography and F-18 fluorodeoxyglucose: comparison with CT and US. Radiology. 1995;195(2):345-52. [pmid: 7724751].
Jemal A, Murray T, Samuels A, Ghafoor A, Ward E, Thun MJ. Cancer statistics, 2003. CA Cancer J Clin. Jan–Feb. 2003;53(1):5-26. [pmid: 12568441].
Janus TJ, Kim EE, Tilbury R, et al. Use of [18F]fluorodeoxyglucose positron emission tomography in patients with primary malignant brain tumors. Annals of Neurology. 1993;33(5):540-8. [pmid: 8498831].
Jimenez-Bonilla J, et al. Clinical impact of 18F-FDG-PET in the suspicion of recurrent ovarian carcinoma based on elevated tumor marker serum levels. Clin Positron Imaging. Nov. 2000;3(6):231-236. [pmid: 11378435].
Kahn D, Follett KA, Bushnell DL, et al. Diagnosis of recurrent brain tumor: value of 201Tl SPECT vs. 18F-fluorodeoxyglucose PET. AJR. American Journal of Roentgenology. 1994;163(6):1459-65. [pmid: 7992747].
Kalady MF, Clary BM, Clark LA, et al. Clinical utility of positron emission tomography in the diagnosis and management of periampullary neoplasms. Annals of Surgical Oncology. 2002;9(8):799-806. [pmid: 12374664].
Karlan BY, Hawkins R, Hoh C, et al. Whole-body positron emission tomography with 2-[18F]-fluoro-2-deoxy-D-glucose can detect recurrent ovarian carcinoma. Gynecologic Oncology. 1993;51(2):175-81. [pmid: 8276290].
Kaschten B, Stevenaert A, Sadzot B, et al. Preoperative evaluation of 54 gliomas by PET with fluorine-18-fluorodeoxyglucose and/or carbon-11-methionine. Journal of Nuclear Medicine. 1998;39(5):778-85. [pmid: 9591574].
Kato T, Fukatsu H, Ito K, et al. Fluorodeoxyglucose positron emission tomography in pancreatic cancer: an unsolved problem. European Journal of Nuclear Medicine. 1995;22(1):32-9. [pmid: 7698152].
Keogan MT, Tyler D, Clark L, et al. Diagnosis of pancreatic carcinoma: role of FDG PET. AJR. American Journal of Roentgenology. 1998;171(6):1565-70. [pmid: 9843289].
Kleihues P, Burger PC, Scheithauer BW. The new WHO classification of brain tumours. Brain Pathology. 1993;3:255-68. [pmid: 8293185].
Kollmannsberger C, Oechsle K, Dohmen BM, et al. Prospective comparison of [18F]fluorodeoxyglucose positron emission tomography with conventional assessment by computed tomography scans and serum tumor markers for the evaluation of residual masses in patients with nonseminomatous germ cell carcinoma. Cancer. 2002;94(9):2353-62. [pmid: 12015760].
Koyama K, Okamura T, Kawabe J, et al. Diagnostic usefulness of FDG PET for pancreatic mass lesions. Annals of Nuclear Medicine. 2001;15(3):217-24. [pmid: 11545191].
Leitao MM Jr, Chi DS. Recurrent cervical cancer. Current Treatment Options in Oncology. Apr. 2002;3(2):105-11. Review. [pmid: 12057073].
Lin WC, Hung YC, Yeh LS, et al. Usefulness of (18)F-fluorodeoxyglucose positron emission tomography to detect para-aortic lymph nodal metastasis in advanced cervical cancer with negative computed tomography findings. Gynecologic Oncology. 2003;89(1):73-6. [pmid: 12694656].
Marchioli CC, Graziano SL. Paraneoplastic syndromes associated with small cell lung cancer. Chest Surg Clin North Am. 1997;7:65-80.
Maringhini A, Ciambra M, Raimondo M, et al. Clinical presentation and ultrasonography in the diagnosis of pancreatic cancer. Pancreas. 1993;8:146-50. [pmid: 8460088].
Marom EM, McAdams HP, Erasmus JJ, et al. Staging non-small cell lung cancer with whole-body PET. Radiology. 1999;212:803-9. [pmid: 10478250].
McGuire WP, Hoskins WJ, Brady MF, Kucera PR, Partridge EE, Look KY, Clarke-Pearson DL, Davidson M. Cyclophosphamide and cisplatin compared with paclitaxel and cisplatin in patients with stage III and stage IV ovarian cancer. New England Journal of Medicine. Jan. 4. 1996;334(1):1-6. [pmid: 7494563].
Mertz HR, Sechopoulos P, Delbeke D, et al. EUS, PET, and CT scanning for evaluation of pancreatic adenocarcinoma. Gastrointestinal Endoscopy. 2000;52(3):367-71. [pmid: 10968852].
Meyer PT, Schreckenberger M, Spetzger U, et al. Comparison of visual and ROI-based brain tumour grading using 18F-FDG PET: ROC analyses. European Journal of Nuclear Medicine. 2001;28(2):165-74. [pmid: 11303886].
Miller TR, Pinkus E, Dehdashti F, et al. Improved prognostic value of 18F-FDG PET using a simple visual analysis of tumor characteristics in patients with cervical cancer. Journal of Nuclear Medicine. 2003;44(2):192-7. [pmid: 12571208].
Nakamoto Y, Eisbruch A, Achtyes ED, et al. Prognostic value of positron emission tomography using F-18-fluorodeoxyglucose in patients with cervical cancer undergoing radiotherapy. Gynecologic Oncology. 2002;84(2):289-95. [pmid: 11812089].
Nakamoto Y, Higashi T, Sakahara H, et al. Delayed (18)F-fluoro-2-deoxy-D-glucose positron emission tomography scan for differentiation between malignant and benign lesions in the pancreas. Cancer. 2000;89(12):2547-54. [pmid: 11135214].
Nakamoto Y, Higashi T, Sakahara H, et al. Contribution of PET in the detection of liver metastases from pancreatic tumours. Clinical Radiology. 1999;54(4):248-52. [pmid: 10210345].
Nakamoto Y, Saga T, Ishimori T, et al. Clinical value of positron emission tomography with FDG for recurrent ovarian cancer. [comment]. AJR. American Journal of Roentgenology. 2001;176(6):1449-54. [pmid: 11373212].
Nuutinen JM, Leskinen S, Elomaa I, et al. Detection of residual tumours in postchemotherapy testicular cancer by FDG-PET. European Journal of Cancer. 1997;33(8):1234-41. [pmid: 9301449].
Olivero WC, Dulebohn SC, Lister JR. The use of PET in evaluating patients with primary brain tumours: is it useful?. Journal of Neurology, Neurosurgery & Psychiatry. 1995;58(2):250-2.
Ozols RF. Update of the NCCN ovarian cancer practice guidelines. Oncology (Huntington). Nov. 1997;11(11A):95-105.
Pandit N, Gonen M, Krug L, et al. Prognostic value of [18F]FDG-PET imaging in small cell lung cancer. European Journal of Nuclear Medicine & Molecular Imaging. 2003;30(1):78-84. [pmid: 12483413].
Papos M, Takacs T, Tron L, et al. The possible role of F-18 FDG positron emission tomography in the differential diagnosis of focal pancreatic lesions. Clinical Nuclear Medicine. 2002;27(3):197-201. [pmid: 11852308].
Park DH, Kim KH, Park SY, et al. Diagnosis of recurrent uterine cervical cancer: computed tomography versus positron emission tomography. Korean Journal of Radiology. 2000;1(1):51-5. [pmid: 11752929].
Patel AM, Davila DG, Peter SG. Paraneoplastic syndromes associated with lung cancer. Mayo Clinic Proceedings. 1993;68:278-287. [pmid: 8474272].
Pieterman RM, Van Putton JWG, Meuzelaar JJ, et al. Preoperative staging of non-small cell lung cancer with positron emission tomography. New England Journal of Medicine. 2000;343:254-61. [pmid: 10911007].
Portelance L, Chao KS, Grigsby PW, et al. Intensity-modulated radiation therapy (IMRT) reduces small bowel, rectum, and bladder doses in patients with cervical cancer receiving pelvic and para-aortic irradiation. International Journal of Radiation Oncology, Biology and Physics. Sep. 1. 2001;51(1):261-6.
Rajput A, Stellato TA, Faulhaber PF, et al. The role of fluorodeoxyglucose and positron emission tomography in the evaluation of pancreatic disease. Surgery. 1998;124(4):793-7. discussion 797–8. [pmid: 9781003].
Rees JH, Hain SF, Johnson MR, et al. The role of [18F]fluoro-2-deoxyglucose-PET scanning in the diagnosis of paraneoplastic neurological disorders. Brain. 2001;124(Pt 11):2223-31. [pmid: 11673324].
Reinhardt MJ, Ehritt-Braun C, Vogelgesang D, et al. Metastatic lymph nodes in patients with cervical cancer: detection with MR imaging and FDG PET. Radiology. 2001;218(3):776-82. [pmid: 11230656].
Rose DM, Delbeke D, Beauchamp RD, et al. 18Fluorodeoxyglucose-positron emission tomography in the management of patients with suspected pancreatic cancer. [Review] [42 refs]. Annals of Surgery. 1999;229(5):729-37. discussion 737–8. [pmid: 10235532].
Rose PG, Adler LP, Rodriguez M, et al. Positron emission tomography for evaluating para-aortic nodal metastasis in locally advanced cervical cancer before surgical staging: a surgicopathologic study. Journal of Clinical Oncology. 1999;17(1):41-5. [pmid: 10458216].
Rose PG, Faulhaber P, Miraldi F, et al. Positive emission tomography for evaluating a complete clinical response in patients with ovarian or peritoneal carcinoma: correlation with second-look laparotomy. Gynecologic Oncology. 2001;82(1):17-21. [pmid: 11426956].
Rothman KJ, Greenland S. Modern Epidemiology. Jan. 15. 1998.
Ryu SY, Kim MH, Choi SC, et al. Detection of early recurrence with 18F-FDG PET in patients with cervical cancer. Journal of Nuclear Medicine. 2003;44(3):347-52. [pmid: 12620999].
Sasaki M, Kuwabara Y, Yoshida T, et al. A comparative study of thallium-201 SPET, carbon-11 methionine PET and fluorine-18 fluorodeoxyglucose PET for the differentiation of astrocytic tumours. European Journal of Nuclear Medicine. 1998;25(9):1261-9. [pmid: 9724375].
Saunders CAB, Dussek JE, O’Doherty MJ, et al. Evaluation of Flourine-18-fluorodeoxyglucose whole body positron emission tomography imaging in the staging of lung cancer. Annals of Thoracic Surgery. 1999;67:790-7. [pmid: 10215230].
Scheidler J, Hricak H, Yu KK, et al. Radiological evaluation of lymph node metastases in patients with cervical cancer. A meta-analysis. Journal of the American Medical Association. Oct. 1. 1997;278(13):1096-101. [pmid: 9315770].
Schumacher T, Brink I, Mix M, et al. FDG-PET imaging for the staging and follow-up of small cell lung cancer. European Journal of Nuclear Medicine. 2001;28(4):483-8. [pmid: 11357499].
Sendler A, Avril N, Helmberger H, et al. Preoperative evaluation of pancreatic masses with positron emission tomography using 18F-fluorodeoxyglucose: diagnostic limitations. World Journal of Surgery. 2000;24(9):1121-9. [pmid: 11036292].
Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Research. 2002;22(2B):1257-64. [pmid: 12168935].
Sperti C, Pasquali C, Chierichetti F, et al. Value of 18-fluorodeoxyglucose positron emission tomography in the management of patients with cystic tumors of the pancreas. Annals of Surgery. 2001;234(5):675-80. [pmid: 11685032].
Stephens AW, Gonin R, Hutchins GD, et al. Positron emission tomography evaluation of residual radiographic abnormalities in postchemotherapy germ cell tumor patients. Journal of Clinical Oncology. 1996;14(5):1637-41. [pmid: 8622082].
Stokkel M, Stevens H, Taphoorn M, et al. Differentiation between recurrent brain tumour and post-radiation necrosis: the value of 201Tl SPET versus 18F-FDG PET using a dual-headed coincidence camera--a pilot study. Nuclear Medicine Communications. 1999;20(5):411-7. [pmid: 10404525].
Sugawara Y, Eisbruch A, Kosuda S, et al. Evaluation of FDG PET in patients with cervical cancer. Journal of Nuclear Medicine. 1999;40(7):1125-31. [pmid: 10405131].
Sugawara Y, Zasadny KR, Grossman HB, et al. Germ cell tumor: differentiation of viable tumor, mature teratoma, and necrotic tissue with FDG PET and kinetic modeling. Radiology. 1999;211(1):249-56. [pmid: 10189480].
Sun SS, Chen TC, Yen RF, et al. Value of whole body 18F-fluoro-2-deoxyglucose positron emission tomography in the evaluation of recurrent cervical cancer. Anticancer Research. 2001;21(4B):2957-61. [pmid: 11712793].
Torizuka T, Nobezawa S, Kanno T, et al. Ovarian cancer recurrence: role of whole-body positron emission tomography using 2-[fluorine-18]-fluoro-2-deoxy- D-glucose. European Journal of Nuclear Medicine & Molecular Imaging. 2002;29(6):797-803. [pmid: 12029554].
Trede M, Schwall G, Saeger D. Survival after pancreatico-duadenectomy. 118 consecutive resections without an operative mortality. Annals of Surgery. 1990;211:447-58. [pmid: 2322039].
Tsatalpas P, Beuthien-Baumann B, Kropp J, et al. Diagnostic value of 18F-FDG positron emission tomography for detection and treatment control of malignant germ cell tumors. Urologia Internationalis. 2002;68(3):157-63. [pmid: 11919460].
Warshaw Al, Fernandez-Del Castillo C. Pancreatic carcinoma. New England Journal Medicine. 1992;326:455-56.
Yeh LS, Hung YC, Shen YY, et al. Detecting para-aortic lymph nodal metastasis by positron emission tomography of 18F-fluorodeoxyglucose in advanced cervical cancer with negative magnetic resonance imaging findings. Oncology Reports. 2002;9(6):1289-92. [pmid: 12375036].
Yen RF, Sun SS, Shen YY, et al. Whole body positron emission tomography with 18F-fluoro-2-deoxyglucose for the detection of recurrent ovarian cancer. Anticancer Research. 2001;21(5):3691-4. [pmid: 11848544].
Zhao DS, Valdivia AY, Li Y, et al. 18F-fluorodeoxyglucose positron emission tomography in small-cell lung cancer. Seminars in Nuclear Medicine. 2002;32(4):272-5. [pmid: 12524651].
Zimny M, Bares R, Fass J, et al. Fluorine-18 fluorodeoxyglucose positron emission tomography in the differential diagnosis of pancreatic carcinoma: a report of 106 cases. European Journal of Nuclear Medicine. 1997;24(6):678-82. [pmid: 9169578].
Zimny M, Siggelkow W, Schroder W, et al. 2-[Fluorine-18]-fluoro-2-deoxy-d-glucose positron emission tomography in the diagnosis of recurrent ovarian cancer. [comment]. Gynecologic Oncology. 2001;83(2):310-5. [pmid: 11606090].