# General Limitations of the Literature Reviewed

A variety of limitations of the literature can affect the interpretation of evidence related to the use of PET. First, PET is a rapidly evolving technology and, as such, information from a somewhat older generation of equipment may not always be applicable to the newest generation. This limitation may be particularly salient to PET in which there have been advances in the hardware used to acquire the raw data (e.g. the advent of hybrid PET/CT scanners) and the software used to generate an image based on that raw data (e.g. attenuation-correction). Second, the literature regarding PET often does not directly address a focused clinical question, such as those posed by CMS. For example, a common limitation was the inclusion of a heterogeneous population of patients without presentation of results by clinically relevant subgroups. Another common limitation was the absence of data that would allow the reader to infer the information contributed by PET beyond what was available from conventional studies. In some cases the data is presented in a way that only permits an estimate of the operating characteristics of PET versus other technologies; in other cases no comparator was considered at all.

Despite these limitations, there is, for the most part, a meaningful body of evidence that serves to inform the deliberations by CMS regarding the use of FDG-PET in specific cancers.