# METHODS

## 2.1 Classification of Diagnostic Studies

The Medicare Coverage Advisory Committee (MCAC) report on “Recommendations for Evaluating Effectiveness; Executive Committee Working Group Medicare Coverage Policy” (Executive Committee Working Group, 2001) developed recommendations for evaluating evidence. Although the preference is for direct evidence, few studies directly measure the effect of diagnostic tests on health outcomes. Studies of these tests typically focus on technical feasibility or operating characteristics.

Thus, in order to provide a framework for systematically identifying and reviewing relevant studies, we used a classification described by Fryback and Thornbury (Fryback, 1991). For each clinical question, we classified articles into a hierarchy of Categories, from 1 through 6 as described by Fryback et al (1991). According to the MCAC assessment criteria, the studies most useful for assessing FDG-PET are Category 2 or higher, since Category 1 articles relate to technologies that are under development rather than routinely used in clinical practice. After consultation with AHRQ and CMS, it was decided that only Category 2 or higher articles would be included in the evidence report and reviewed in-depth. Since the majority of studies fell into Category 1 or 2, we used pre-specified criteria for determining which of the two categories was applicable to a particular article.

For studies in Categories 2 to 6, we identified study design features that would ideally address the goal of that category. These study design features were then used to develop a quality score for each article. The elements of the score were based on commonly accepted study design criteria for obtaining unbiased estimates of sensitivity and specificity (Rothman and Greenland, 1998) and were as follows:

1. Use of a prospective design. This type of study is the most flexible since it allows for investigator control over the design of the study and data collection. In particular, the investigator can enroll patients consecutively, develop and implement standard protocols for the collection of study data, including pre-specifying cut points for determining test positive and test negative patients. This type of design would allow for appropriate blinding of radiologists and pathologists instead of relying on retrospective chart review, which may lead to selection biases in terms of the patients included in the study and limitations in terms of available data for answering the study question.
2. Use of a matched study design, in which FDG PET and the comparator test are both obtained on one patient or use of a randomized controlled trial, in which patients are randomly assigned to receive FDG-PET or the comparator test. These designs reduce the possibility of confounding due to differences in patient characteristics (sex, age, distribution of underlying disease) that may result in biased estimates of test accuracy.
3. Use of a pre-specified cut-point to determine sensitivity and specificity. This was a key criteria for categorizing studies as Category 1 (technical feasibility) or Category 2 (diagnostic accuracy). In order for the results obtained from a given technology to be reproducible across different settings and populations, there needs to be commonly accepted criteria for determining which patients have a positive or negative test result. Studies that do not pre-specify a cut-point would usually be considered technical feasibility studies rather than diagnostic accuracy studies. These studies form the basis for determining the optimal cut-point. This cut-point can, in turn, be used to standardize test positive and test negative patients across different populations thus ensuring reproducibility of study results.
4. Availability of histology or long-term follow-up information on all patients. In order to determine the true disease status for all patients, an independent gold standard is usually needed. Ideally the results from this gold standard, whether it be pathology or long-term follow-up, should be obtained blinded to all test results. Determining true disease status unblinded to one or more test results may result in a higher estimate of sensitivity for a given test than would be obtained if true disease status was unknown.

The Fryback categories, criteria for distinguishing between Category 1 and 2, and hallmarks of an ideal study design for Category 2 (or higher) articles are summarized in Table 1.

Table 1 Relationship between clinical question, Fryback et al.

Category and study design (for Categories 1 and 2 only)

CLINICAL QUESTION | CATEGORY | CATEGORY DESCRIPTION | MEASURES | STUDY DESIGN
Does the test have good technical characteristics that make it appropriate for use in a clinical setting? | 1. | Technical feasibility and optimization | Ability to produce consistent spectra | Study presents patient specific data i.e. SUV’s but does not categorize the data using pre- specified cut-points
Does the test have good operating characteristics that make it useful for; 1. determining the presence of disease?; 2. determining the severity of disease?; 3. improving the yield of specimens for diagnosing disease? | 2. | Diagnostic accuracy | Sensitivity and specificity % yield of abnormal diagnoses | Ideal studies for answering this question; 1. are prospective; 2. are randomized controlled trials or matched studies that obtain test information on all patients; 3. use a pre-specified cut-point to determine % positive or negative; 1. obtain histology or long-term follow-up information on all patients to determine true disease status
Does the test influence the clinicians’ subjective assessment of disease status? | 3. | Diagnostic thinking impact | Difference in clinician’s subjectively estimated diagnosis probabilities pre and post-test
Does the test influence the therapy given to a patient? | 4. | Therapeutic choice impact | % of times therapy planned prior to PET changed after PET
Does the test result in an improvement in life expectancy from the patient viewpoint? | 5. | Patient outcome impact | % of patients who improved with PET compared to % without PET Cost per QALY saved with image information
Does the test result in an improvement in life expectancy at a reasonable cost from the viewpoint of society? | 6. | Societal impact | Cost-benefit or cost- effectiveness analysis conducted from a societal viewpoint

## 2.2 Literature Review

### 2.2.1 Literature Identification

An OVID search of the Medline database was conducted on April 18^th^, 2003. Filters and limitations were used to eliminate inappropriate publications. General inclusion criteria were included to maximize the applicability of the search results to the SOW questions (see below Section 2.2.2.1). The search used applicable MeSH headings and text words with appropriate Boolean operators. After filtering irrelevant publication types, the search resulted in 1058 citations for download and screening. Individual review of the abstracts resulted in 226 citations identified for complete article review.

#### 2.2.1.1 Search Strategy Used for Identifying Abstracts

Ovid Technologies, Inc. Email Service

Search for: 9 and 39

Citations: 1

Database: MEDLINE <1966 to April Week 1 2003>

Search Strategy:

1. brain neoplasms/ (49633)
2. exp brain neoplasms/ (71050)
3. exp glioma/ (31687)
4. or/2–3 (81482)
5. testicular neoplasms/ (14494)
6. exp "neoplasms, germ cell and embryonal"/ (175246)
7. or/5–6 (181892)
8. Cervix Neoplasms/ (33177)
9. exp endometrial neoplasms/ (5954)
10. exp lung neoplasms/ (88849)
11. exp paraneoplastic syndromes/ (8184)
12. Carcinoma, Small Cell/ (12646)
13. or/10–12 (97789)
14. exp Pancreatic Neoplasms/ (27054)
15. exp ovarian neoplasms/ (34704)
16. ca-125 antigen/ (1244)
17. ca-125.mp. (2705)
18. or/15–17 (35859)
19. exp *Tomography, Emission-Computed/ (16259)
20. positron emission tomography.mp. (10892)
21. fdg-pet.mp. (1900)
22. or/19–21 (22228)
23. 4 and 22 (1024)
24. exp tomography, emission-computed/ (30872)
25. or/20–21,24 (32462)
26. 4 and 25 (1369)
27. 26 not 23 (345)
28. exp Deoxyglucose/du [Diagnostic Use] (4254)
29. 4 and 28 (244)
30. 29 not 26 (8)
31. 29 not 23 (21)
32. fluorodeoxyglucose.mp. (2079)
33. or/21,28,32 (5157)
34. 4 and 33 (327)
35. 23 not 24 (77)
36. 23 not 34 (723)
37. limit 34 to (human and English language and yr=1990–2003) (237)
38. "fdg pet".mp. (1900)
39. limit 33 to (human and English language and yr=1990–2003) (3661)
40. 7 and 39 (302)
41. 8 and 39 (26)
42. 9 and 39 (5)
43. 13 and 39 (388)
44. 14 and 39 (65)
45. 18 and 39 (38)

### 2.2.2 Literature Selection

#### 2.2.2.1 General Inclusion/Exclusion Criteria for Identifying Abstracts

Two levels of inclusion criteria were used for accepting studies. The first were general criteria applied during the initial literature search, and were as follows:

- English language articles reporting primary data and published in a peer review journal (not abstracts)
- Studies that include at least 12 human subjects (not animal studies) with one of the conditions of interest and technology of interest (PET)

#### 2.2.2.2 Inclusion Criteria for Identifying Articles for Full Text Review

A second level of inclusion criteria was applied to all articles (n= 226) identified for full text review based on a review of the abstracts. Prior to full text review, these articles were screened to ensure that they answered at least one of the SOW questions. If an article was only a Category 1 article, it was excluded as discussed previously.

For Category 2 or higher articles, inclusion criteria were applied as follows:

Category 2 Diagnostic accuracy efficacy
  A reference standard had to be obtained on all patients.
Category 3 Diagnostic thinking impact
  No additional criteria
Category 4 Therapeutic choice impact
  No additional criteria
Category 5 Patient outcome impact
  Limitation to 12 human subjects relaxed if simulation modeling, with hypothetical populations, used to calculate survival/quality-adjusted life expectancy
Category 6 Societal impact
  Limitation to 12 human subjects relaxed if simulation modeling, with hypothetical populations, used to calculate cost-effectiveness or cost-benefit ratios

### 2.2.3 Data Abstraction and Quality Scores Assigned to Full Text Articles

Data on patient population characteristics, PET scanner, conventional imager, criteria for test positivity, results of tests including sensitivity, specificity and prevalence of cancer was abstracted using a data abstraction form (refer to Appendix C for form).

A quality score was assigned to each article identified for full text data abstraction. In addition to the criteria used to describe an ideal study design for determining test accuracy (prospective, matched or randomized assignment of patients receive tests, pre-specified threshold for determining test accuracy, independent confirmation of disease status (gold standard) obtained on all patients), additional criteria for determining the quality of a given study were developed and applied during data abstraction. These criteria were as follows:

1. The study had a representative sample
2. The setting and selection of the population under investigation were clearly described
3. The study design minimized differences between patients who received the tests
4. The scanner model or the type and resolution of the scanner were mentioned
5. Defined criteria were used for test interpretation
6. Histopathological or clinical confirmation of disease were mentioned
7. The test reader and person assigning the reference standard diagnosis were blinded

Quality scores were determined by adding up the points assigned (from 0 to 7) based on an in-depth review of each article. Each article was reviewed by at least two reviewers. Discrepancies between reviewers were resolved by consensus. Articles were ranked using the score from 0 to 7 and are presented in the results section for each cancer, grouped by scores of either 4 through 7 or 0 through 3, to provide the reader with a general impression of the quality of the articles available for answering a specific question.