# INTRODUCTION

## 1.1 Overview

Computed tomography (CT) and magnetic resonance (MRI) are anatomic, high-resolution imaging techniques currently used in oncology to detect or confirm the presence of a tumor; to provide information about the size and location of the tumor and whether it has spread; to guide a biopsy; to help plan radiation therapy or surgery; and to determine whether the cancer is responding to treatment. Despite widespread use, concerns remain that use of these imaging techniques may result in false negatives due to their inability to resolve small volumes (diameter < 1cm) of disease and false positives due to their inability to distinguish between viable tumor masses and masses consisting of necrotic or scar tissue.

Functional imaging methods such as positron emission tomography (PET) can establish the metabolic or functional parameters of tissue that may aid in these distinctions. Instead of using anatomical deviations to identify areas of abnormality, PET uses positron-emitting radioactive tracer that accumulates in abnormal tissue. Therefore, it primarily measures metabolism and function as opposed to structure. The process involves release of a positron from a radioisotope (e.g. 18-fluorine), which subsequently collides with an electron, forming two photons in a process called annihilation. The two photons travel away from each other at 180° angles and are picked up by detectors placed around the body. The source of the photons is then spatially determined. Areas with increased photon activity are areas of radioisotope accumulation. Quantitative measurements can be made when photon attenuation, which occurs during passage through the body, is corrected using a transmission scan. Semi-quantitative measurement is performed using the standardized uptake value (SUV) of a region of interest. The SUV is calculated by measuring the tissue radioactivity concentration (μCi/mL) and dividing by the total injected dose (μCi/kg), normalized to the body weight. Results may be variable depending upon the scanner image resolution (should be small enough to adequately visualize the organ or region of interest), time of image acquisition after radioisotope injection (later images will have higher SUVs as FDG accumulates), the presence of hyperglycemia, method of normalization (use of body surface area or lean body mass) and the method of quantitative measurement.

The most commonly used radioisotope tracer is ^18^Fluro-deoxyglucose (FDG), a glucose analog. Like glucose FDG is taken up into cells through glucose transport proteins (GLUT) and then phosphorylated by a hexokinase. At this point glucose is further metabolized while deoxyglucose is not, leaving the ^18^FDG to accumulate intra-cellularly as ^18^F-FDG-6-phosphate. Some tissues contain glucose-6-phosphatase, which can dephosphorylate the molecule returning it to its original form as ^18^FDG. Tumor cells have both an overexpression of GLUT and an under expression of glucose-6-phosphatase, permitting a relatively large localized accumulation of tracer molecules within the tumor cells. In addition, depending on the area or organ under study, baseline glucose metabolism may be low, further establishing the difference between normal background tissue and tumor. Thus, compared to structural imaging techniques, FDG-PET may be a more accurate technique for diagnosis, staging and treatment decisions in oncology.

PET is currently approved for coverage by the Center for Medicaid and Medicare Services (CMS) for use, for certain indications, in non-small cell lung cancer, esophageal cancer, colorectal cancer, lymphoma, melanoma, breast cancer, head and neck cancers and thyroid cancer (http://www.cms.hhs.gov/coverage/ accessed September 27^th^, 2003).

## 1.2 Request by the Centers for Medicare and Medicaid Services

The Centers for Medicare & Medicaid Services (CMS) requested a technology assessment by the Agency for Health Care Research and Quality (AHRQ) to evaluate the performance of FDG-PET when compared to conventional imaging (such as CT and MRI) and when used as an adjunct to conventional imaging for patient management of six different cancers (brain, cervical, ovarian, pancreatic, small cell lung, and testicular). The Duke Evidence-based Practice Center was asked to conduct an assessment of this technology. In particular, the key questions to be addressed were:

### 1.2.1 Brain Cancer

1. How does the diagnostic test performance of FDG-PET, as an adjunct to conventional imaging (e.g. CT, MRI), compare to conventional imaging alone with respect to the following clinical situations in primary brain tumors (i.e. not tumors metastatic to brain):
  a. In performing guided lesion biopsy of recurrent low-grade brain tumors in patients with an indeterminate MRI?
  b. In distinguishing high-grade from low-grade tumors and distinguishing tumor from radiation necrosis in recurrent brain lesions?
2. How does the diagnostic test performance of FDG-PET, as an adjunct to biopsy, compare to biopsy alone with respect to the following clinical situation:
  a. In the initial grading of the degrees of malignancy for patients with primary brain tumors when the initial biopsy result was indeterminate grade II/III glioma?

### 1.2.2 Cervical Cancer

1. How does the diagnostic test performance of FDG-PET compare to conventional imaging (e.g., CT, lymphangiography, chest radiograph, IV pyelography) in the detection of pre-treatment metastases in newly diagnosed cervical cancer?
2. How does the diagnostic test performance of FDG-PET compare to conventional imaging (e.g., CT, MRI) in the following clinical situations:
  a. In detection of residual cervical cancer following treatment (surgery, radiation, chemotherapy, or combination)?
  b. In detection of recurrent cervical cancer following treatment (surgery, radiation, chemotherapy, or combination)?

### 1.2.3 Ovarian Cancer

1. How does the diagnostic test performance of FDG-PET as an adjunct to conventional imaging (e.g., CT, MRI) compare to conventional imaging alone in the following clinical situations:
  a. In staging at the time of initial diagnosis?
  b. In detecting recurrent disease following treatment (surgery, radiation, chemotherapy, or combination)?
    As a subset within this indication, does FDG-PET accurately and reliably detect recurrence in a patient with a history of ovarian cancer who has a rising CA-125 titer and a negative CT:
    i. In determining if there has been a recurrence of the tumor?
    ii. In localizing, if present, such recurrence?
    iii. In yielding appropriate staging of such recurrence?
  c. In monitoring the effect of chemotherapy

### 1.2.4 Pancreatic Cancer

1. How does the diagnostic test performance of FDG-PET as an adjunct to conventional imaging (e.g., CT, MRI, endoscopic ultrasound) compare to conventional imaging alone in the following clinical situations:
  a. In differentiating benign from malignant pancreatic lesions?
  b. In detecting metastatic pancreatic cancer?
2. If adjunctive use of FDG-PET is superior to conventional imaging alone for detection of metastatic pancreatic cancer, for what subpopulation(s) of patients has this superiority been shown?
3. How does FDG-PET compare to conventional imaging (e.g. MRI, CT) for detection of residual or recurrent disease following treatment of primary pancreatic cancer?

### 1.2.5 Small Cell Lung Cancer

1. How does the diagnostic test performance of FDG-PET compare to conventional imaging modalities (e.g., CT, MRI) with respect to the following clinical situations:
  b In staging to determine the true extent of disease at initial diagnosis in patients with small cell lung cancer (SCLC)?
  c In restaging post treatment to evaluate the response to initial treatment (detect residual or new disease sites) in patients with SCLC?
  d In diagnosing occult small cell lung cancer in patients with paraneoplastic syndrome(s) commonly associated with this neoplasm?

### 1.2.6 Testicular Cancer

1. In patients with an established diagnosis of pure seminomas or non-seminomatous germ cell tumors, how does the diagnostic test performance of FDG-PET compare to conventional imaging modalities (e.g., CT, MRI) or histology with respect to the following clinical situations:
  a. For initial staging?
  b. In evaluation of residual masses or suspected recurrent disease to reliably distinguish between viable tumor and fibrosis/necrosis?
  c. In determining if there has been a recurrence of tumor in patients with rising serum tumor markers and a normal CT?

## 1.3 Structure of the Evidence Report

Generally, the questions that CMS posed relate to the overall accuracy of conventional imaging compared to FDG-PET for one or more of the following: (1) initial staging, (2) monitoring response to therapy, and (3) detection of recurrence. In order to address these questions and for ease in reading and comprehension, the report is arranged with a general methods section applicable to all the cancers. The remainder of the report is organized by cancer type; each section addressing a particular cancer is organized so that it can be considered a stand-alone report and includes a general review of the cancer in question, the relevance of the questions posed regarding FDG-PET to clinical management of the specific cancer, and a text summary of the results of the identified studies. In addition, to facilitate an overview of the studies, we provided both a table and a figure summarizing the test performance (sensitivity, specificity, with 95% confidence intervals). At the end of the document, we have placed the bibliography and appendices, which include the detailed evidence tables ordered by cancer type (brain, cervical, ovarian, pancreatic, small cell lung and testicular).