# References

Albers P, Bender H, Yilmaz H, et al. Positron emission tomography in the clinical staging of patients with Stage I and II testicular germ cell tumors. Urology. 1999;53(4):808-11. [pmid: 10197862].
Bader JB, Samnick S, Moringlane JR, et al. Evaluation of l-3-[123I]iodo-alpha-methyltyrosine SPET and [18F]fluorodeoxyglucose PET in the detection and grading of recurrences in patients pretreated for gliomas at follow-up: a comparative study with stereotactic biopsy. European Journal of Nuclear Medicine. 1999;26(2):144-51. [pmid: 9933348].
Bares R, Klever P, Hauptmann S, et al. F-18 fluorodeoxyglucose PET in vivo evaluation of pancreatic glucose metabolism for detection of pancreatic cancer. Radiology. 1994;192(1):79-86. [pmid: 8208970].
Bares R, Klever P, Hellwig D, et al. Pancreatic cancer detected by positron emission tomography with 18F-labelled deoxyglucose: method and first results. Nuclear Medicine Communications. 1993;14(7):596-601. [pmid: 8355920].
Barker FG 2nd, Chang SM, Valk PE, et al. 18-Fluorodeoxyglucose uptake and survival of patients with suspected recurrent malignant glioma. Cancer. 1997;79(1):115-26. [pmid: 8988735].
Belhocine T, Thille A, Fridman V, et al. Contribution of whole-body 18FDG PET imaging in the management of cervical cancer. Gynecologic Oncology. 2002;87(1):90-7. [pmid: 12468348].
Chang WC, Hung YC, Kao CH, et al. Usefulness of whole body positron emission tomography (PET) with 18F-fluoro-2-deoxyglucose (FDG) to detect recurrent ovarian cancer based on asymptomatically elevated serum levels of tumor marker. Neoplasma. 2002;49(5):329-33. [pmid: 12458332].
Chin R Jr, McCain TW, Miller AA, et al. Whole body FDG-PET for the evaluation and staging of small cell lung cancer: a preliminary study. [comment]. Lung Cancer. 2002;37(1):1-6. [pmid: 12057859].
Cho SM, Ha HK, Byun JY, et al. Usefulness of FDG PET for assessment of early recurrent epithelial ovarian cancer. AJR. American Journal of Roentgenology. 2002;179(2):391-5. [pmid: 12130439].
Cremerius U, Effert PJ, Adam G, et al. FDG PET for detection and therapy control of metastatic germ cell tumor. Journal of Nuclear Medicine. 1998;39(5):815-22. [pmid: 9591582].
Cremerius U, Wildberger JE, Borchers H, et al. Does positron emission tomography using 18-fluoro-2-deoxyglucose improve clinical staging of testicular cancer?--Results of a study in 50 patients. Urology. 1999;54(5):900-4. [pmid: 10565755].
De Santis M, Bokemeyer C, Becherer A, et al. Predictive impact of 2-18fluoro-2-deoxy-D-glucose positron emission tomography for residual postchemotherapy masses in patients with bulky seminoma. [erratum appears in J Clin Oncol 2001 Dec 1;19(23):4355]. Journal of Clinical Oncology. 2001;19(17):3740-4. [pmid: 11533096].
De Witte O, Lefranc F, Levivier M, et al. FDG-PET as a prognostic factor in high-grade astrocytoma. Journal of Neuro-Oncology. 2000;49(2):157-63. [pmid: 11206011].
Delbeke D, Meyerowitz C, Lapidus RL, et al. Optimal cutoff levels of F-18 fluorodeoxyglucose uptake in the differentiation of low-grade from high-grade brain tumors with PET. Radiology. 1995;195(1):47-52. [pmid: 7892494].
Delbeke D, Rose DM, Chapman WC, et al. Optimal interpretation of FDG PET in the diagnosis, staging and management of pancreatic carcinoma. Journal of Nuclear Medicine. 1999;40(11):1784-91. [pmid: 10565771].
Deshmukh A, Scott JA, Palmer EL, et al. Impact of fluorodeoxyglucose positron emission tomography on the clinical management of patients with glioma. Clinical Nuclear Medicine. 1996;21(9):720-5. [pmid: 8879874].
Diederichs CG, Staib L, Vogel J, et al. Values and limitations of 18F-fluorodeoxyglucose-positron-emission tomography with preoperative evaluation of patients with pancreatic masses. Pancreas. 2000;20(2):109-16. [pmid: 10707924].
Friess H, Langhans J, Ebert M, et al. Diagnosis of pancreatic cancer by 2[18F]-fluoro-2-deoxy-D-glucose positron emission tomography. [erratum appears in Gut 1995 Sep;37(3):448]. Gut. 1995;36(5):771-7. [pmid: 7797130].
Ganjoo KN, Chan RJ, Sharma M, et al. Positron emission tomography scans in the evaluation of postchemotherapy residual masses in patients with seminoma. Journal of Clinical Oncology. 1999;17(11):3457-60. [pmid: 10550142].
Grigsby PW, Siegel BA, Dehdashti F. Lymph node staging by positron emission tomography in patients with carcinoma of the cervix. Journal of Clinical Oncology. 2001;19(17):3745-9. [pmid: 11533097].
Grigsby PW, Siegel BA, Dehdashti F, et al. Posttherapy surveillance monitoring of cervical cancer by FDG-PET. International Journal of Radiation Oncology, Biology, Physics. 2003;55(4):907-13.
Hain SF, O'Doherty MJ, Timothy AR, et al. Fluorodeoxyglucose PET in the initial staging of germ cell tumours. European Journal of Nuclear Medicine. 2000;27(5):590-4. [pmid: 10853816].
Hain SF, O'Doherty MJ, Timothy AR, Leslie MD, Harper PG, Huddart RA. Fluorodeoxyglucose positron emission tomography in the evaluation of germ cell tumours at relapse. Br J Cancer. 2000;83:863-869. [pmid: 10970686].
Ho CL, Dehdashti F, Griffeth LK, et al. FDG-PET evaluation of indeterminate pancreatic masses. Journal of Computer Assisted Tomography. 1996;20(3):363-9. [pmid: 8626891].
Hubner KF, McDonald TW, Niethammer JG, et al. Assessment of primary and metastatic ovarian cancer by positron emission tomography (PET) using 2-[18F]deoxyglucose (2-[18F]FDG). Gynecologic Oncology. 1993;51(2):197-204. [pmid: 8276294].
Imdahl A, Nitzsche E, Krautmann F, et al. Evaluation of positron emission tomography with 2-[18F]fluoro-2-deoxy-D-glucose for the differentiation of chronic pancreatitis and pancreatic cancer. British Journal of Surgery. 1999;86(2):194-9. [pmid: 10100786].
Inokuma T, Tamaki N, Torizuka T, et al. Evaluation of pancreatic tumors with positron emission tomography and F-18 fluorodeoxyglucose: comparison with CT and US. Radiology. 1995;195(2):345-52. [pmid: 7724751].
Janus TJ, Kim EE, Tilbury R, et al. Use of [18F]fluorodeoxyglucose positron emission tomography in patients with primary malignant brain tumors. Annals of Neurology. 1993;33(5):540-8. [pmid: 8498831].
Jimenez-Bonilla J, et al. Clinical impact of 18F-FDG-PET in the suspicion of recurrent ovarian carcinoma based on elevated tumor marker serum levels. Clin Positron Imaging. Nov. 2000;3(6):231-236. [pmid: 11378435].
Kahn D, Follett KA, Bushnell DL, et al. Diagnosis of recurrent brain tumor: value of 201Tl SPECT vs. 18F-fluorodeoxyglucose PET. AJR. American Journal of Roentgenology. 1994;163(6):1459-65. [pmid: 7992747].
Kalady MF, Clary BM, Clark LA, et al. Clinical utility of positron emission tomography in the diagnosis and management of periampullary neoplasms. Annals of Surgical Oncology. 2002;9(8):799-806. [pmid: 12374664].
Karlan BY, Hawkins R, Hoh C, et al. Whole-body positron emission tomography with 2-[18F]-fluoro-2-deoxy-D-glucose can detect recurrent ovarian carcinoma. Gynecologic Oncology. 1993;51(2):175-81. [pmid: 8276290].
Kaschten B, Stevenaert A, Sadzot B, et al. Preoperative evaluation of 54 gliomas by PET with fluorine-18-fluorodeoxyglucose and/or carbon-11-methionine. Journal of Nuclear Medicine. 1998;39(5):778-85. [pmid: 9591574].
Kato T, Fukatsu H, Ito K, et al. Fluorodeoxyglucose positron emission tomography in pancreatic cancer: an unsolved problem. European Journal of Nuclear Medicine. 1995;22(1):32-9. [pmid: 7698152].
Keogan MT, Tyler D, Clark L, et al. Diagnosis of pancreatic carcinoma: role of FDG PET. AJR. American Journal of Roentgenology. 1998;171(6):1565-70. [pmid: 9843289].
Kollmannsberger C, Oechsle K, Dohmen BM, et al. Prospective comparison of [18F]fluorodeoxyglucose positron emission tomography with conventional assessment by computed tomography scans and serum tumor markers for the evaluation of residual masses in patients with nonseminomatous germ cell carcinoma. Cancer. 2002;94(9):2353-62. [pmid: 12015760].
Koyama K, Okamura T, Kawabe J, et al. Diagnostic usefulness of FDG PET for pancreatic mass lesions. Annals of Nuclear Medicine. 2001;15(3):217-24. [pmid: 11545191].
Lin WC, Hung YC, Yeh LS, et al. Usefulness of (18)F-fluorodeoxyglucose positron emission tomography to detect para-aortic lymph nodal metastasis in advanced cervical cancer with negative computed tomography findings. Gynecologic Oncology. 2003;89(1):73-6. [pmid: 12694656].
Mertz HR, Sechopoulos P, Delbeke D, et al. EUS, PET, and CT scanning for evaluation of pancreatic adenocarcinoma. Gastrointestinal Endoscopy. 2000;52(3):367-71. [pmid: 10968852].
Meyer PT, Schreckenberger M, Spetzger U, et al. Comparison of visual and ROI-based brain tumour grading using 18F-FDG PET: ROC analyses. European Journal of Nuclear Medicine. 2001;28(2):165-74. [pmid: 11303886].
Miller TR, Pinkus E, Dehdashti F, et al. Improved prognostic value of 18F-FDG PET using a simple visual analysis of tumor characteristics in patients with cervical cancer. Journal of Nuclear Medicine. 2003;44(2):192-7. [pmid: 12571208].
Nakamoto Y, Eisbruch A, Achtyes ED, et al. Prognostic value of positron emission tomography using F-18-fluorodeoxyglucose in patients with cervical cancer undergoing radiotherapy. Gynecologic Oncology. 2002;84(2):289-95. [pmid: 11812089].
Nakamoto Y, Higashi T, Sakahara H, et al. Delayed (18)F-fluoro-2-deoxy-D-glucose positron emission tomography scan for differentiation between malignant and benign lesions in the pancreas. Cancer. 2000;89(12):2547-54. [pmid: 11135214].
Nakamoto Y, Higashi T, Sakahara H, et al. Contribution of PET in the detection of liver metastases from pancreatic tumours. Clinical Radiology. 1999;54(4):248-52. [pmid: 10210345].
Nakamoto Y, Saga T, Ishimori T, et al. Clinical value of positron emission tomography with FDG for recurrent ovarian cancer. [comment]. AJR. American Journal of Roentgenology. 2001;176(6):1449-54. [pmid: 11373212].
Nuutinen JM, Leskinen S, Elomaa I, et al. Detection of residual tumours in postchemotherapy testicular cancer by FDG-PET. European Journal of Cancer. 1997;33(8):1234-41. [pmid: 9301449].
Olivero WC, Dulebohn SC, Lister JR. The use of PET in evaluating patients with primary brain tumours: is it useful?. Journal of Neurology, Neurosurgery & Psychiatry. 1995;58(2):250-2.
Pandit N, Gonen M, Krug L, et al. Prognostic value of [18F]FDG-PET imaging in small cell lung cancer. European Journal of Nuclear Medicine & Molecular Imaging. 2003;30(1):78-84. [pmid: 12483413].
Papos M, Takacs T, Tron L, et al. The possible role of F-18 FDG positron emission tomography in the differential diagnosis of focal pancreatic lesions. Clinical Nuclear Medicine. 2002;27(3):197-201. [pmid: 11852308].
Park DH, Kim KH, Park SY, et al. Diagnosis of recurrent uterine cervical cancer: computed tomography versus positron emission tomography. Korean Journal of Radiology. 2000;1(1):51-5. [pmid: 11752929].
Rajput A, Stellato TA, Faulhaber PF, et al. The role of fluorodeoxyglucose and positron emission tomography in the evaluation of pancreatic disease. Surgery. 1998;124(4):793-7. discussion 797–8. [pmid: 9781003].
Rees JH, Hain SF, Johnson MR, et al. The role of [18F]fluoro-2-deoxyglucose-PET scanning in the diagnosis of paraneoplastic neurological disorders. Brain. 2001;124(Pt 11):2223-31. [pmid: 11673324].
Reinhardt MJ, Ehritt-Braun C, Vogelgesang D, et al. Metastatic lymph nodes in patients with cervical cancer: detection with MR imaging and FDG PET. Radiology. 2001;218(3):776-82. [pmid: 11230656].
Rose PG, Adler LP, Rodriguez M, et al. Positron emission tomography for evaluating para-aortic nodal metastasis in locally advanced cervical cancer before surgical staging: a surgicopathologic study. Journal of Clinical Oncology. 1999;17(1):41-5. [pmid: 10458216].
Rose PG, Faulhaber P, Miraldi F, et al. Positive emission tomography for evaluating a complete clinical response in patients with ovarian or peritoneal carcinoma: correlation with second-look laparotomy. Gynecologic Oncology. 2001;82(1):17-21. [pmid: 11426956].
Ryu SY, Kim MH, Choi SC, et al. Detection of early recurrence with 18F-FDG PET in patients with cervical cancer. Journal of Nuclear Medicine. 2003;44(3):347-52. [pmid: 12620999].
Sasaki M, Kuwabara Y, Yoshida T, et al. A comparative study of thallium-201 SPET, carbon-11 methionine PET and fluorine-18 fluorodeoxyglucose PET for the differentiation of astrocytic tumours. European Journal of Nuclear Medicine. 1998;25(9):1261-9. [pmid: 9724375].
Schumacher T, Brink I, Mix M, et al. FDG-PET imaging for the staging and follow-up of small cell lung cancer. European Journal of Nuclear Medicine. 2001;28(4):483-8. [pmid: 11357499].
Sendler A, Avril N, Helmberger H, et al. Preoperative evaluation of pancreatic masses with positron emission tomography using 18F-fluorodeoxyglucose: diagnostic limitations. World Journal of Surgery. 2000;24(9):1121-9. [pmid: 11036292].
Shen YY, Shiau YC, Wang JJ, et al. Whole-body 18F-2-deoxyglucose positron emission tomography in primary staging small cell lung cancer. Anticancer Research. 2002;22(2B):1257-64. [pmid: 12168935].
Sperti C, Pasquali C, Chierichetti F, et al. Value of 18-fluorodeoxyglucose positron emission tomography in the management of patients with cystic tumors of the pancreas. Annals of Surgery. 2001;234(5):675-80. [pmid: 11685032].
Stephens AW, Gonin R, Hutchins GD, et al. Positron emission tomography evaluation of residual radiographic abnormalities in postchemotherapy germ cell tumor patients. Journal of Clinical Oncology. 1996;14(5):1637-41. [pmid: 8622082].
Stokkel M, Stevens H, Taphoorn M, et al. Differentiation between recurrent brain tumour and post-radiation necrosis: the value of 201Tl SPET versus 18F-FDG PET using a dual-headed coincidence camera--a pilot study. Nuclear Medicine Communications. 1999;20(5):411-7. [pmid: 10404525].
Sugawara Y, Eisbruch A, Kosuda S, et al. Evaluation of FDG PET in patients with cervical cancer. Journal of Nuclear Medicine. 1999;40(7):1125-31. [pmid: 10405131].
Sugawara Y, Zasadny KR, Grossman HB, et al. Germ cell tumor: differentiation of viable tumor, mature teratoma, and necrotic tissue with FDG PET and kinetic modeling. Radiology. 1999;211(1):249-56. [pmid: 10189480].
Sun SS, Chen TC, Yen RF, et al. Value of whole body 18F-fluoro-2-deoxyglucose positron emission tomography in the evaluation of recurrent cervical cancer. Anticancer Research. 2001;21(4B):2957-61. [pmid: 11712793].
Torizuka T, Nobezawa S, Kanno T, et al. Ovarian cancer recurrence: role of whole-body positron emission tomography using 2-[fluorine-18]-fluoro-2-deoxy- D-glucose. European Journal of Nuclear Medicine & Molecular Imaging. 2002;29(6):797-803. [pmid: 12029554].
Tsatalpas P, Beuthien-Baumann B, Kropp J, et al. Diagnostic value of 18F-FDG positron emission tomography for detection and treatment control of malignant germ cell tumors. Urologia Internationalis. 2002;68(3):157-63. [pmid: 11919460].
Yeh LS, Hung YC, Shen YY, et al. Detecting para-aortic lymph nodal metastasis by positron emission tomography of 18F-fluorodeoxyglucose in advanced cervical cancer with negative magnetic resonance imaging findings. Oncology Reports. 2002;9(6):1289-92. [pmid: 12375036].
Yen RF, Sun SS, Shen YY, et al. Whole body positron emission tomography with 18F-fluoro-2-deoxyglucose for the detection of recurrent ovarian cancer. Anticancer Research. 2001;21(5):3691-4. [pmid: 11848544].
Zhao DS, Valdivia AY, Li Y, et al. 18F-fluorodeoxyglucose positron emission tomography in small-cell lung cancer. Seminars in Nuclear Medicine. 2002;32(4):272-5. [pmid: 12524651].
Zimny M, Bares R, Fass J, et al. Fluorine-18 fluorodeoxyglucose positron emission tomography in the differential diagnosis of pancreatic carcinoma: a report of 106 cases. European Journal of Nuclear Medicine. 1997;24(6):678-82. [pmid: 9169578].
Zimny M, Siggelkow W, Schroder W, et al. 2-[Fluorine-18]-fluoro-2-deoxy-d-glucose positron emission tomography in the diagnosis of recurrent ovarian cancer. [comment]. Gynecologic Oncology. 2001;83(2):310-5. [pmid: 11606090].