# Glossary

## Abbreviations Used in the Text

AFP: Alpha fetoprotein
AHRQ: Agency for Healthcare Research and Quality
ANP: Atrial natriuretic peptide
beta HCG: beta subunit of human chorionic gonadotropin
CI: Confidence interval
cm: Centimeter(s)
CMS: Centers for Medicare and Medicaid Services
CNS: Central nervous system
CS: Clinical stage
CT: Computed Tomography
DAR: Differential absorption ratio
DUR: Differential uptake ratio
ERCP: Endoscopic retrograde cystopancreatogram
EUS: Endoscopic ultrasound
FDG: 2-Fluro 2-deoxy D-glucose
^18^FDG: 18-Fluro-deoxy-glucose
g: Gram(s)
FIGO: International Federation of Gynecology and Obstetrics
FN: False Negative
FP: False Positive
GCT: Germ cell tumor
GLUT: Glucose transport proteins
kg: Kilogram(s)
LDH: Lactose dehydrogenase
MCAC: Medicare Coverage Advisory Committee
MBq: MegaBaquerels
μCi: Microcuries
μg: Microgram(s)
mg: Milligram
mL: Milliliter(s)
MRI: Magnetic Resonance Imaging
NSGCT: Non-seminomatous germ cell tumor
NSCLC: Non-small cell lung cancer
PET: Positron emission tomography
PNS: Peripheral nervous system
PS: Pathologic stage
RCT: Randomized control trials
RI: Retention Index
RPLND: Retroperitoneal lymph node dissection
SCLC: Small cell lung cancer
SIADH: Inappropriate secretion of antidiuretic hormone
SN: Sensitivity
SOW: Statement of work
SP: Specificity
SUR: Standardized uptake ratio
SUV: Standardized uptake value
Thallium-SPECT: Thallium Single photon emission tomography
US: Ultrasound
VA: Veterans Administration
vs.: Versus
WHO: World Health Organization
%: percent