# Neuroepithelial Tumors of the CNS (Kleihues,1993)

1. Astrocytic tumors [glial tumors--categories I–V, below--may also be subclassified as invasive or non-invasive, although this is not formally part of the WHO system, the non-invasive tumor types are indicated below. Categories in italics are also not recognized by the new WHO classification system, but are in common use.]
  1. Astrocytoma (WHO grade II)
    1. variants: protoplasmic, gemistocytic, fibrillary, mixed
  2. Anaplastic (malignant) astrocytoma (WHO grade III)
    1. hemispheric
    2. diencephalic
    3. optic
    4. brain stem
    5. cerebellar
  3. Glioblastoma multiforme (WHO grade IV)
    1. variants: giant cell glioblastoma, gliosarcoma
  4. Pilocytic astrocytoma [non-invasive, WHO grade I]
    1. hemispheric
    2. diencephalic
    3. optic
    4. brain stem
    5. cerebellar
  5. Subependymal giant cell astrocytoma [non-invasive, WHO grade I]
  6. Pleomorphic xanthoastrocytoma [non-invasive, WHO grade I]
2. Oligodendroglial tumors
  1. Oligodendroglioma (WHO grade II)
  2. Anaplastic (malignant) oligodendroglioma (WHO grade III)
3. Ependymal cell tumors
  1. Ependymoma (WHO grade II)
    1. variants: cellular, papillary, epithelial, clear cell, mixed
  2. Anaplastic ependymoma (WHO grade III)
  3. Myxopapillary ependymoma
  4. Subependymoma (WHO grade I)
4. Mixed gliomas
  1. Mixed oligoastrocytoma (WHO grade II)
  2. Anaplastic (malignant) oligoastrocytoma (WHO grade III)
  3. Others (e.g. ependymo-astrocytomas)
5. Neuroepithelial tumors of uncertain origin
  1. Polar spongioblastoma (WHO grade IV)
  2. Astroblastoma (WHO grade IV)
  3. Gliomatosis cerebri (WHO grade IV)
6. Tumors of the choroid plexus
  1. Choroid plexus papilloma
  2. Choroid plexus carcinoma (anaplastic choroid plexus papilloma)
7. Neuronal and mixed neuronal-glial tumors
  1. Gangliocytoma
  2. Dysplastic gangliocytoma of cerebellum (Lhermitte-Duclos)
  3. Ganglioglioma
  4. Anaplastic (malignant) ganglioglioma
  5. Desmoplastic infantile ganglioglioma
    1. desmoplastic infantile astrocytoma
  6. Central neurocytoma
  7. Dysembryoplastic neuroepithelial tumor
  8. Olfactory neuroblastoma (esthesioneuroblastoma)
    1. variant: olfactory neuroepithelioma
8. Pineal Parenchyma Tumors
  1. Pineocytoma
  2. Pineoblastoma
  3. Mixed pineocytoma/pineoblastoma
9. Tumors with neuroblastic or glioblastic elements (embryonal tumors)
  1. Medulloepithelioma
  2. Primitive neuroectodermal tumors with multipotent differentiation
    1. medulloblastoma
      1. variants: medullomyoblastoma, melanocytic medulloblastoma, desmoplastic medulloblastoma
    2. cerebral primitive neuroectodermal tumor
  3. Neuroblastoma
    1. variant: ganglioneuroblastoma
  4. Retinoblastoma
  5. Ependymoblastoma

## Other CNS Neoplasms

1. Tumors of the Sellar Region
  1. Pituitary adenoma
  2. Pituitary carcinoma
  3. Craniopharyngioma
2. Hematopoietic tumors
  1. Primary malignant lymphomas
  2. Plasmacytoma
  3. Granulocytic sarcoma
  4. Others
3. Germ Cell Tumors
  1. Germinoma
  2. Embryonal carcinoma
  3. Yolk sac tumor (endodermal sinus tumor)
  4. Choriocarcinoma
  5. Teratoma
  6. Mixed germ cell tumors
4. Tumors of the Meninges
  1. Meningioma
    1. variants: meningothelial, fibrous (fibroblastic), transitional (mixed), psammomatous, angiomatous, microcystic, secretory, clear cell, chordoid, lymphoplasmacyte-rich, and metaplastic subtypes
  2. Atypical meningioma
  3. Anaplastic (malignant) meningioma
5. Non-menigothelial tumors of the meninges
  1. Benign Mesenchymal
    1. osteocartilaginous tumors
    2. lipoma
    3. fibrous histiocytoma
    4. others
  2. Malignant Mesenchymal
    1. chondrosarcoma
    2. hemangiopericytoma
    3. rhabdomyosarcoma
    4. meningeal sarcomatosis
    5. others
  3. Primary Melanocytic Lesions
    1. diffuse melanosis
    2. melanocytoma
    3. maliganant melanoma
      1. variant meningeal melanomatosis
  4. Hemopoietic Neoplasms
    1. malignant lymphoma
    2. plasmactoma
    3. granulocytic sarcoma
  5. Tumors of Uncertain Histogenesis
    1. hemangioblastoma (capillary hemangioblastoma)
6. Tumors of Cranial and Spinal Nerves
  1. Schwannoma (neurinoma, neurilemoma)
    1. cellular, plexiform, and melanotic subtypes
  2. Neurofibroma
    1. circumscribed (solitary) neurofibroma
    2. plexiform neurofibroma
  3. Malignant peripheral nerve sheath tumor (Malignant schwannoma)
    1. epithelioid
    2. divergent mesenchymal or epithelial differentiation
    3. melanotic
7. Local Extensions from Regional Tumors
  1. Paraganglioma (chemodectoma)
  2. Chordoma
  3. Chodroma
  4. Chondrosarcoma
  5. Carcinoma
8. Metastatic tumours
9. Unclassified Tumors
10. Cysts and Tumor-like Lesions
  1. Rathke cleft cyst
  2. Epidermoid
  3. Dermoid
  4. Colloid cyst of the third ventricle
  5. Enterogenous cyst
  6. Neuroglial cyst
  7. Granular cell tumor (choristoma, pituicytoma)
  8. hypothalamic neuronal hamartoma
  9. nasal glial herterotopia
  10. plasma cell granuloma