# SUMMARY OF EVIDENCE ABOUT TEST CHARACTERISTICS

## Types of Fecal Occult Blood Tests

The fecal occult blood test (FOBT) is a test for blood or blood products in the stool. Neoplasia of the bowel mucosa, particularly larger neoplasia, has a tendency to bleed periodically. Consequently the test for blood in the stool is used as a marker for neoplasia. Van Deen in 1864 reported that gum guaiac, a natural resin extracted from wood, is useful in detecting occult blood. Greegor (1967) suggested the use of fecal occult blood tests in the diagnosis of colorectal cancer. In the 1970’s the 3-window slide kit was developed (Fleisher 2003).

There are currently two major types of FOBT which are commercially available: guaiac and immunochemical tests. The guaiac-based test reacts positive to pseudoperoxidase activity of heme in the feces and is not specific for human blood. This is a limitation of this test because false positive tests can be due to the presence of plant and animal materials. In order to reduce the number of false positive tests, the guaiac-based test requires dietary restrictions (no red meat, certain uncooked vegetables, vitamin C, and nonsteroidal anti-inflammatory drugs (NSAIDS)) prior to and during administration of the test which requires specimens from 3 bowel movements. A meta-analysis based on Hemoccult II studies suggest that dietary restrictions are not required when using guaiac FOBT (Pignone 2001) but Young (2002) suggests that the Pignone review did not take into account dietary differences between different ethnic groups. In contrast the immunochemical fecal occult blood test is designed to detect the globin protein of human hemoglobin and is also specific for blood in the large intestines rather than for blood originating from other sources higher up in the gastrointestinal tract (Young 2002).

Guaiac tests such as Hemoccult can be developed and interpreted in an office setting whereas immunochemical tests may require development in a centralized laboratory setting (Australian Health Technology Advisory Committee, 1997). The two main guaiac tests in use in the US are the Hemoccult II and Hemoccult SENSA tests. The newer Hemoccult SENSA test has improved readability and stability over that of the Hemoccult II test (Young 2003). However inaccurate training can lead to inaccurate reading of these tests (Fleisher 1991). Although the Clinical Laboratory Improvement Amendments (CLIA) of 1988 considered the guaiac tests (Hemoccult II and Hemoccult SENSA) as waived laboratory tests (Ransohoff and Lang 199&), new regulations are now requiring proficiency testing for those performing fecal occult blood tests. For example in New York State there are regulatory requirements regarding quality control and documentation for point of care testing. In order to mandate this requirements Memorial Sloan-Kettering Cancer Center has eliminated the performance of fecal occult blood tests at the point of care and has recommended processing for the FOBT’s in a central facility which can be monitored for accuracy. The immunochemical tests are more amenable to standardized development and quality control (Young, 2002). Originally the immunochemical tests used enzyme-linked immunosorbent assay (ELISA) and double immunodiffusion methods. Latex agglutination tests and qualitative hemagglutination tests have been used more recently. Latex tests can be used in the physician’s office (Young, 1996). Immunochemical tests include HemeSelect (Immudia Hem Sp, an older version of HemeSelect), FlexSure OBT, and Monahaem. Some immunochemical tests that have been evaluated are no longer marketed (i.e. FlexSure OBT) and some new tests are coming on the market (InSure). The FDA has registered over 50 types of FOBT in the United States but only a few tests have been evaluated for screening in population studies. (Young 2002)

In a review by Young, St. John, Winawer, and Rozen (2002) test positivity is reported to be highest with rehydrated Hemoccult II, and successively lower for Hemoccult SENSA, immunochemical FOBT, and then lowest for Hemoccult II (un-rehydrated). The order is reversed for specificity with Hemoccult II having the highest specificity. In regard to test sensitivity for the detection of colorectal cancer and other neoplasia, Hemoccult II results in the lowest values, while sensitivity is highest for Hemoccult SENSA and rehydrated Hemoccult and IFOBT’s yield intermediate sensitivities. Another characteristic of the IFOBT, as mentioned, is that it is specific for occult blood in the large intestine. Consequently a positive IFOBT with no detectable colon or rectal problem (polyps or hemorrhoids) will not result in a further upper GI series work-up.

There is a third type of fecal occult blood test based on the technology of heme-porphyrin assays which are specific for dicarboxylic porphisa and detect heme in any form and its degradation products. Hemoquant is a test based on this method. The heme-porphyrin assays require fluorescent spectrometry which makes this a more complex type of fecal occult test (Young 1996). The heme-porphyrin assay tests are not discussed further in this report.

## Study designs for estimating FOBT sensitivity and specificity for colorectal cancer and adenomatous polyps used in available studies

### FOBT followed by colonoscopy as the gold standard for all

The probability that a one-time fecal occult blood test (and follow-up diagnostic procedures) will detect a lesion, e.g. colorectal cancer, when such a lesion is actually present, is the [underlined: event sensitivity] of FOBT. The empirical measure that most directly corresponds to this concept of event sensitivity is the performance of a gold-standard test for the presence of colorectal cancer or adenomas, such as colonoscopy, immediately following the performance of an FOBT. Even this approach falls short of measuring true event sensitivity because it is known that colonoscopy, itself, does not have 100% sensitivity to detect all colorectal cancers and adenomas. Evidence from back to back colonoscopy examinations (Rex 1997) and follow-up colonoscopy (Ee 2002) indicates that colonoscopy achieves close to 100% sensitivity for detection of colorectal cancer while at least 6% of large adenomas (≥1 cm), 13% of moderate sized adenomas (0.6–0.9 cm) and 27% of small adenomas (≤ 0.5 cm) are missed (Rex 1997). Nevertheless, high quality colonoscopy is the best gold standard available.

Studies using contemporaneous colonoscopy as a gold standard however are modest in size. The majority of findings at colonoscopy are adenomas rather than cancer. Due to the small number of colorectal cancers detected, sensitivity estimates for cancers may be imprecise or the sensitivity estimate may be based on combining colorectal cancers and adenomas rather than for colorectal cancer alone. Further these types of studies are usually based on high-risk populations atypical for screening populations. Therefore these sensitivity values are difficult to directly compare to sensitivity values for cancer derived from very large screening trials.

### Follow-up of positive tests with colonoscopy and negative tests with surveillance of at least one year

Another type of study relies on follow-up of positive FOBT’s with colonoscopy and then monitoring patient’s records for a year or more following negative FOBT and recording instances of clinically detected cancer. Such studies are likely to over-estimate sensitivity for cancer compared to studies that use contemporaneous colonoscopy as a gold standard. This is because some cancers present at the time of FOBT testing have not yet become clinically manifest. On the other hand, new cancers may have developed after the FOBT testing and become evident during the follow-up period. These studies are generally not suitable for estimating sensitivity for adenomas because most adenomas are asymptomatic. Studies, which employ different follow-up periods, i.e. one year following FOBT versus 2 or 3 years, can provide different measures of sensitivity and are not directly comparable. In some of these surveillance studies multiple fecal occult blood tests are compared and a positive on any of the tests would be followed by a colonoscopic evaluation. Such studies provide relative sensitivity of one test to another but not an absolute measure of sensitivity. Such relative comparisons over-estimate sensitivity because false negatives are under-represented. A listing of studies which use relative sensitivity is given in Table 1F.

### Randomized controlled trials of screening

Finally, sensitivity is also estimated from randomized controlled trials of screening involving periodic screening, counting “interval” cancers, cancers clinically detected between the screening interval following a negative screening test, as evidence of a false negative test. Sensitivity directly observed by this last method does not correspond to event sensitivity but, rather, is a measure of “[underlined: program sensitivity]”. In most cases, program sensitivity will be higher than event sensitivity. This is because for trials of annual or biennial FOBT screening, the average interval between screening tests is shorter than the average sojourn time, the time that it takes an undetected lesion (i.e. a preclinical invasive colorectal cancer) to develop into a clinically detectable cancer. Thus, a lesion that is missed by a first screening test may have some probability of being detected by a second or third test before it would have, in the absence of screening, been clinically detected. For example Church (1997), shows that high program sensitivity for FOBT of 90% in the context of a single cohort clinical trial of periodic screening can be consistent with an event sensitivity of less than 30%. Mathematical methods can be used to simultaneously estimate event sensitivity and the preclinical duration of the lesion from screening trial data. (Gyrd-Hansen 1997, Prevost 1997). Notice that the sensitivity measured in trials is not only affected by test sensitivity for cancers but also by sensitivity of adenomas – which when removed, reduce the risk of subsequent cancers. The mathematical model can and should account for this mechanism.

## Summary of the evidence on sensitivity and specificity of FOBT

Table 1 summarizes estimates of FOBT test sensitivity and specificity (for any neoplasia - cancer or adenomas) for Hemoccult II, Hemoccult SENSA, and immunochemical FOBT. Sensitivity is presented for colorectal cancer, for large adenomas (>1 cm) and for small adenomas (<1 cm). There was generally insufficient data to provide separate sensitivity estimates for Duke’s A/B and for Duke’s C/D stage of cancer. The estimates are derived from several different types of sources including clinical series that monitor for positive follow-up tests and surveillance for at least one year following the initial FOBT and clinical series or studies that compare the results of FOBT to colonoscopy conducted immediately following FOBT and large randomized controlled screening studies. In addition we present values of FOBT sensitivity and specificity that have been assumed in other cost-effectiveness studies, in clinical guideline documents and in package insert literature from the manufacturer.

Table 1 Summary of Studies Reporting Sensitivity and Specificity for FOBT

Table 1A GUAIAC Hemoccult II (un-rehydrated and rehydrated)

Author | Ref | Year | N in Study | Country | Sensitivity CRC | Sensitivity Large Aden | Sensitivity Small Aden | Specificity
Literature with follow-up of positive tests with colonoscopy and negative tests with surveillance of at least one year
Hemoccult II [underlined: un-rehydrated]
Allison | N Eng J Med | 1996 | 8065 | US | 37.1 | 30.1 | | 98.1
Petrilli | Surg Onc | 1994 | 8933 | US | 37.1 | | | 98.1
Robinson | BrJ Surg | 1994 | 1489 | UK | 11.1 | | | 98.9
Hemoccult II rehydrated
Castiglione | BrJCa | 1996 | 8008 | Italy | 68.2 | 52.9 | | 94.1
Randomized controlled trials
Hemoccult II un-rehydrated
Mandel | N Engl J Med | 1993 | 45,000 | US | 80.8 | | | 97.7
Hardcastle | Lancet | 1996 | 150,000 | UK | 58.6 | | | 96.8
Kronborg | Lancet | 1996 | 60,000 | Denmark | 55.5 (62.1) | | | 99.3
Gyrd-Hansen | In J Epi | 1997 | (60,000) | Denmark | 62.1
Hemoccult II rehydrated
Mandel | N Engl J Med | 1993 | 45,000 | US | 92.2 | | | 90.4
Church | JNCI | 1997 | (45,000) | US | 90.0
Literature with FOBT followed by Colonoscopy for all
Hemoccult II un-rehydrated
Greenberg | AmJ Gast | 2000 | 554 | 9 centers in world | 85.7 | 20.5 | | 92.8
Zauber | DDW | 2002 | 881 | US | | 23 | | 91
Hemoccult II rehydrated
Lieberman | N Engl J Med | 2001 | 2885 | US | 50% | 21.6 | 7.0 | 93.8

Table 1B GUAIAC Hemoccult SENSA

Author | Ref | Year | N in Study | Country | Sensitivity CRC | Sensitivity Large Aden | Sensitivity Small Aden | Specificity
Literature with follow-up of positive tests with colonoscopy and negative tests with or without* surveillance of at least one year
Allison | N Engl J Med | 1996 | 8065 | US | 79.4 | 68.6 | | 87.5
Cole* | Gastro Enterolgy | 2003 | 460 | Australia | 38.5 | | | Not reported
Literature with FOBT followed by Colonoscopy for all
Greenberg | AmJ Gast | 2000 | 554 | 9 centers in world | 78.6 | 35.9 | | 90.5

Table 1C Immunochemical

Author | Ref | Year | N in Study | Country | Sensitivity CRC | Sensitivity Large Aden | Sensitivity Small Aden | Specificity
Literature with follow-up of positive tests with colonoscopy and negative tests with surveillance of at least one year
HemeSelect
Allison | N Engl J Med | 1996 | 8065 | | 68.8 | 66.7 | | 95.2
Robinson | BrJSurg | 1994 | 1489 | UK | 100 | | | 90.8 (94.9)
Castiglione* | BrJCa | 1996 | 8008 | Italy | 95.5 | 78.6 | | 92.0 (92.7)
(Castiglione**) | BrJCa | 1996 | 8008 | Italy | 77.3 | 51.4 | | 97.1 (97.6)
Monahaem
Nakama | Prev Med | 1994 | 3365 | Japan | 91 | | | 96
Nakama | JmedSc | 1996 | 3365 | Japan | 71.4 | | | 95.6
Nakama | Hep-Gastr | 1999 | 4611 | Japan | 88.9 | | | 93.1
*1 day positive plus borderline **1 day positive only
Insure
Cole | Gastro | 2003 | 460 | Australia | 85 | | | Not given in abstract
Randomized controlled trials
None
Literature with FOBT followed by colonoscopy (or flexible sigmoidoscopy*) for all
Flexsure
Young | J Med Sc | 2003 | | Austral | 80 | | | 97.2
Greenberg | AmJ Gast | 2003 | 554 | World | 87.5 | | | 86.2
HemeSelect
Allison | Gastro | 2002 | 5356 | US | 81.8 | 25.4 | | 97.5
Greenberg | AmJ Gast | 2003 | 554 | World | 83.3 | | | 88.2
Allsion | Gastro | 2002 | 5356 | US | 82 for left crc | 25 | | 97.5
Nakama | Hepato Gas | 1999 | 4611 | Japan | 83.3 | 50.7 | | 96.0
Magstream 1000/Hem SP
Wong | Cancer | 2003 | 250 | China | 62 OR 100? | 47 | | 93
Insure
Young | J Med Scr | 2003 | | Austra | 75 | | | 97.8

Table 1D Package Inserts

Company | Year | Country | Sensitivity CRC | Sensitivity Large Aden | Sensitivity Small Adenomas | Specificity
Guaiac Tests
Hemoccult II un-rehydrated
Beckman-Coulter | 2000 | US | 86 | 53 | 32 | 98
Hemoccult SENSA
Beckman-Coulter | 2000 | US | 92 | 67 | 43 | 96.5
Immunochemical Test
Insure
Enterix | 2003 | US | 87 | 47.4 | | 97.7

Table 1E Estimates from cost-effectiveness assumptions and guidelines

Author | Ref | Year | Sensitivity CRC | Sensitivity Large Aden | Sensitivity Small Aden | Specificity
Cost-Effectiveness Models
Hemoccult II un-rehydrated
Frazier/Kuntz | JAMA | 2000 | 33 | | 2 | 97
MISCAN | Compu | 1999 | 60 | 5 | 2 | 98
Sonnenberg | Ann Int Med | 2000 | 40 | | | 97.5
Wagner | Prev | 1996 | 60 | | | 90
Hemoccult II rehydrated
Frazier/Kuntz | JAMA | 2000 | 60 | | | 90
MISCAN | Compu | 1999 | 70 | 20 | | 90
Kanneker | Int J Tech | 2000 | 60 | 10 | 6 | 92
Guidelines Recommendations
Hemoccult II un-rehydrated
Winawer | Gastroent | 1997 | 60 | | | 90
Australian | Austral Health Tech | 1997 | 50 | 10 | | 92

Table 1F Studies Comparing Multiple FOBT”s

Author | Hemoccult II Unrehydrated | Hemoccult II rehydrated | Hemoccult SENSA | Immunochemical
Allison (1996) | X | | X | HemeSelect
Allison (2002) | | | X | HemeSelect or FlexSure
Castilgone | | X | | HemeSelect (1 day + and +/−)
Robinson | X | | | Hemeselect 3 day
Greenberg | X | | X | HemeSelect and FlexSure
Young | | | | InSure and FlexSure
Cole | | | X | InSure

### HEMOCCULT II

#### Sensitivity for colorectal cancer

The Hemoccult II guaiac based test has been the most widely used colorectal cancer screening test. Although some screening programs in the past used the rehydrated Hemoccult II test with the aim of increasing test sensitivity, rehydration is not considered to be an acceptable means of increasing the sensitivity of the FOBT because of deteriorating specificity (Winawer, 2003). Consequently this report focuses on the estimated value for sensitivity and specificity for the un-rehydrated FOBT. The estimates from the literature for rehydrated FOBT are provided as a reference point but are not the focus for test-parameter estimates. The sensitivity of a single un-rehydrated FOBT is relatively low (range from 11% to 86%) with most estimates around 40% sensitivity for cancer. All persons with a positive Hemoccult II test should be referred for diagnostic colonoscopy.

#### Sensitivity for adenomas

Data for the sensitivity for large and for small adenomas are much more sparse than for colorectal cancer and primarily depend on studies with colonoscopic evaluation following fecal occult blood testing. As noted above these studies tend to be based on higher risk individuals who are already scheduled to have colonoscopy (Table 1). The VA Cooperative Study is a colonoscopy screening study in asymptomatic persons in the VA system (primarily men) with rehydrated FOBT preceding the scheduled colonoscopy. One-time FOBT sensitivity was 23.9% for large adenomas or cancer (50% sensitivity for colorectal cancers and 21.6% for adenomas ≥1.0 cm) (Lieberman 2001). In the National Polyp Study un-rehydrated Hemoccult II tests were performed annually for patients who were under surveillance following initial colonoscopic removal of adenomatous polyps (Zauber 2002). In this surveillance study, Hemoccult II sensitivity for adenomas ≥ 1.cm was 23%. A multi-national trial was conducted of 4 FOBT tests (un-rehydrated Hemoccult II, Hemoccult SENSA, and the immunochemical tests of HemeSelect and FlexSure OBT) on patients referred for colonoscopy for predetermined indications (Greenberg, 2000). Un-rehydrated Hemoccult II sensitivity for cancers was 85.7% and for large adenomas was 20.5%. Some earlier cost-effectiveness studies have assumed lower sensitivity of guaiac FOBT for adenomas. (Wagner 1996, Loeve 2000). We assume that sensitivity of Hemoccult II (un-rehydrated) for large adenomas is 10% which is approximately half that reported in these higher risk screening cohorts and reported for rehydrated Hemoccult II in asymptomatic veterans. We also assume that Hemoccult II sensitivity for smaller adenomas (<1 cm) is only 5% or half that of the assumed value for the larger adenomas. We recognized that there is little data in the literature on sensitivity for adenomas, of larger size (≥ 1 cm) or of smaller size (< 1 cm).

#### Program sensitivity

Values of program sensitivity derived from large randomized trials only apply to guaiac FOBT Hemoccult II (Table 1). The sensitivities reported from the Minnesota screening trial, of 92% for annual screening with rehydrated FOBT and 81% for annual un-rehydrated FOBT are program sensitivities for annual screening. The corresponding specificity values are about 90% and 98%. Event sensitivity and specificity values derived from two European trials, using un-rehydrated FOBT for biennial screening, are in the range of 47%–66% and 97%–99% respectively. Estimates, from other studies, of programmatic sensitivity for rehydrated FOBT range from 68% to 96% with corresponding specificity in the range of 86%–97%.

#### Other cost-effectiveness analyses

Other cost-effective studies, after reviewing similar data, have assumed values for guaiac FOBT sensitivity in the range of 33%–60% for un-rehydrated FOBT and 60%–70% for rehydrated FOBT, with corresponding ranges of specificity of 97%–98% and 90%.

#### Summary of assumptions on un-rehydrated Hemoccult II

##### Sensitivity

We will adopt a conservative assumption for un-rehydrated Hemoccult II of 40% sensitivity for colorectal cancer, 10% sensitivity for adenomas ≥ 1cm, and 5% sensitivity for adenomas < 1 cm. We do not consider rehydrated FOBT in our analysis since its use is currently not recommended by U.S. clinical guidelines (Winawer, 2003).

##### Specificity

Specificity for the un-rehydrated Hemoccult II test for colorectal cancer has been consistently reported as high, between 95.2% to 98.9%. We assume that specificity for not having cancer or adenomas for the Hemoccult II test is 98% on the basis of what has been measured in the randomized trials.

### HEMOCCULT-SENSA

Data on the test characteristics of the guaiac Hemoccult-SENSA and IFOBT are also relatively sparse, with no data for these tests available from large, controlled screening trials. From studies conducted using modest samples of selected patients, some consisting of direct comparisons of these tests and guaiac FOBT, it seems clear that Hemoccult-SENSA results in better sensitivity than un-rehydrated Hemoccult, but with specificity somewhere between that of un-rehydrated and rehydrated Hemoccult. It appears that SENSA may have sensitivity for cancer in the range of 80% with specificity in the range of 90%–94%. We use a conservative estimate of sentitivity and assume in this report that Hemoccult SENSA sensitivity for colorectal cancer is 70%, sensitivity for adenomas ≥ 1 cm is 17%, and sensitivity for adenomas < 1 cm is 9% and a specificity of 92.5%.

### IMMUNOCHEMICAL FECAL OCCULT BLOOD TESTS (IFOBT)

The various studies of IFOBT indicate sensitivity in the same range as for Hemoccult SENSA with perhaps somewhat better specificity, i.e., sensitivity in the range of 70% – 90% with specificity of about 95% in the majority of studies. Other reviews of the literature have come to similar conclusions. (Young 1996, Young 2002). Consequently we consider an immunochemical test with sensitivity of 70% for colorectal cancer and 17% sensitivity for large adenomas and 9% sensitivity for smaller adenomas (the same sensitivities assumed for Hemoccult SENSA) but with higher specificity. We consider IFOBT specificities of 98% and of 95%.

We recognize that there are varying types of IFOBT’s by different manufacturers and that the estimates of sensitivity and specificity vary for each particular type of IFOBT. For example, unlike the chemical-based guaiac tests, immunochemical tests use biological components, particularly antibodies, that can be quite variable. The FlexSure test manufactured by Beckman-Coulter used polyclonal antibodies for both capture and labeling of globin from the stool sample. The InSure test by Enterix uses a monoclonal antibody to always capture globin by the same epitope and with the same affinity consistently from batch to batch of the test manufacture (Young 2003) – personal communication). Also the immunochemical tests are quantitative with respect to the detection of hemoglobin. Consequently the positivity threshold adopted may vary for different tests or in different studies. The positivity threshold adopted can be varied to achieve different postiivity levels for an increased sensitivity with lowered specificty or a decreased sensitivity with an increased specificity. The optimal positivity threshold for IFOBT’s has to address the capacity of the health care system to evalute the postive tests with colonoscopy as well as an assessment in the tradeoffs of life years gained with higher sensitivty and costs incured due to evaluation of false positives if specficity is decreased. For example Ransohff and Lang (1996) suggest that a FOBT should have a specificty of 95% or higher in order to avoid an excessive number of colonoscopy examinations.

Of particular interest is the InSure immunochemical fecal occult blood test (Enterix Corporation) which is recently introduced in the US. This test does not require dietary restrictions, uses a novel brush sampling method for collection, and requires two days of stool sampling rather than the 3 for Hemoccult II or Hemoccult SENSA. The participant samples the stool by briefly burshing the surfce of the stool while immersed in the toilet bowl water. The test has been compared with another immunochemical test (FlexSure OBT) in patients scheduled to undergo diagnostic colonoscopy (Young, in press 2003). The sensitivity and specificity for the two tests were comparable. Also a relative comparison of InSure with Hemocult SENSA showed that InSure had sensitivity of 85% for cancer, 77% for significant neoplasia (cancer or adenomas ≥ 1.0 cm), and 68% for all neoplasia compared to Hemoccult SENSA with sensitivity of 38% for cancer, 50% for significant neoplasia, and 50% for all neoplasia (Cole 2003). These results were based on an average risk screening cohort (n=284), a high risk surveillance cohort (n=158), and a symptomatic diagnostic group (n=18). These results as presented in abstract form stated that InSure provided significantly better sensitivity for colorectal neoplasia without any loss of specificity when compared to Hemoccult SENSA. Also in a randomized trial InSure had a higher participation rate (40%) for completing screening than Hemoccult SENSA (23%) or FlexSure OBT (30%) (Cole, in press 2003).

New data on immunochemical fecal occult blood test sensitivity and specificity is expected in the near future from newer tests. We recognize that the estimates for IFOBT would benefit from upcoming publications on these tests. Consequently for the purposes of this report we present simulations for an immunochemical test with sensitivity 25%, 50%,75%, and 100% higher than that of Hemoccult II. Specificity of 98% and of 95% are considered for the IFOBT with these levels of sensitivities. An immunochemical test with sensitivity 75% greater than the Hemocult II test is the sensitivity level of 70% for colorectal cancer, 17% for large adenomas and 9% for small adenomas which is assumed for the Hemoccult SENSA test and is used as the main assumption for the IFOBTs with a more favorable specificity (98%) and a less favorable specificity (95%).

A two-tier approach combining a sensitive guaiac with an immunochemical test have been considered by Allison (1996, 2002) and Greenberg (2003). A two-tier approach is not included in this report.

The sensitivity and specificity assumptions for the simulation analyses for Hemoccult II, Hemoccult SENSA, and immunochemical tests are given in Table 2.

Table 2 Estimates of sensitivity and specificity for Hemoccult II, Hemoccult SENSA and immunochemical tests assumed for the simulations

FOBT Test | Sensitivity for CRC | Sensitivity for ≥1 cm adenomas | Sensitivity for <1 cm adenomas | Specificity | Base case
Main analyses
Hemoccult II FOBT 40,10,5_98 | 40% | 10% | 5% | 98% | Base
Hemoccult SENSA FOBT 70, 17,9_92.5 | 70% | 17% | 9% | 92.5% | Base
IFOBT70,17,9_98 | 70% | 17% | 9% | 98% | New test
IFOBT_70,17,9_95 | 70% | 17% | 9% | 95% | New test
Sensitivity Analyses of Test Parameters of IFOBT
IFOBT with increased sensitivity compared to Hemoccult II
IFOBT 50,12.5,6.25_98 25%↑Se | 50% | 12% | 6% | 98% | New test
IFOBT 50,12.5,6.25_95 | 50% | 12% | 12% | 95% | New test
IFOBT 60,12.5,6.25_98 50%↑Se | 60% | 15% | 7% | 98% | New test
IFOBT 60,12.5,6.25_95 | 60% | 15% | 7% | 95% | New test
IFOBT 70,17,9_98 75%↑Se | 70% | 17% | 9% | 98% | New test MAIN comparison
IFOBT 70,17,9_95 | 70% | 17% | 9% | 95% | New test MAIN
IFOBT 80,20,10_98 100%↑Se | 80% | 20% | 10% | 98% | New test
IFOBT 80,20,10_95 | 80% | 20% | 10% | 95% | New test
Best case for IFOBT(package insert)
IFOBT 87,48,24_95% | 87 | 48% | 24% | 98% | New test