# RESULTS

We use the simulation model to derive the costs per life year gained for a screening strategy compared to no screening (the average cost effectiveness ratio or ACER) and for one screening strategy compared to another screening strategy (the incremental cost effectiveness ratio or ICER). Difference in colorectal cancer cases and colorectal cancer deaths, total costs, life years gained, and cost-effectiveness ratios (costs per life years saved) with and without discounting are derived for all simulations. Further the simulated results provide for an assessment of different prices for the guaiac FOBT and the IFOBT that will deliver equivalent cost effectiveness ratios. This price is the threshold analysis value.

## Dynamic Results of a Screening Program

The simulation is based on a 30-year period of annual screening. Figure 1 shows the dynamic effects of a typical screening program using annual screening with Hemoccult II. The line labeled “no screening” shows the number of new cases of colorectal cancer that would be detected in the absence of screening. The line labeled “all” shows that total cases of colorectal cancer would decrease during the 30 years of a screening program and after the termination of screening, in 2030, would eventually recover to the no screening level. The lines labeled “clinical,” “scr. det.”, and “surveil. det.” show the number of cases of colorectal cancer that would be detected following clinical symptoms, following positive screening test results and following positive surveillance test results. The mortality benefit from screening occurs because fewer total invasive cancers occur during a screening program, because of the removal of pre-cancerous adenomas, and because cancer detected by screening and surveillance tend to be diagnosed at an earlier and more treatable stage than those that are clinically detected. Cancers that are prevented or those detected at an earlier stage may also result in avoided treatment costs.

Figure 1 Cases of colorectal cancer with no screening program and with a screening Program using Hemoccult II

## Results of Screening: Life Years Saved, Costs, and Cost-Effectiveness

In Table 4 we consider the results of the simulation model for Hemoccult II and Hemoccult SENSA compared to an IFOBT with sensitivity of the Hemoccult SENSA (70%) and specificity of the un-rehydrated Hemoccult II FOBT (98%) or lower (95%). Two costs, $4.50 and $28, are considered for all scenarios. We also consider costs of $18 and $27 for the main assumptions. The cost effectiveness ratios portrayed in Table 4 are very favorable by conventional standards for all fecal occult blood test options. The ACER for programs using Hemoccult II with 40% sensitivity and 98% specificity is approximately $1000 per life year gained when FOBT costs $4.50. IFOBTs with 98% specificity have an ACER lower ($357) than that of Hemoccult II when IFOBT costs $4.50 and still very favorable with an ACER of $2834 if IFOBT costs $28. The more unfavorable ACER is obtained for Hemoccult SENSA which is the test with the lowest assumed specificity (92.5%). However even if Hemoccult SENSA costs $28 per test, the ACER is $5827. Our lowest cost-effectiveness estimates are more favorable than those that have been reported in most other cost-effectiveness studies, but this can be explained by the lower value we have used for the payment level for the test. Compared to the $4.50 level have assumed, other studies assumed test cost from $7.50 to $38.00 (Pignone 2002).

Table 4 Simulated cancers prevented, CRC deaths prevented, life years gained, costs and costs per life year gained from different scenario's. Simulations with MISCAN-colon. Results per 1 million individuals age 65–79 at the beginning of the screening program.

| | | no discounting | | | | 3% discounting
| | Difference | Diff. in | Total Cost | Life Years | Total Cost 3% | Life Years | ACER 3%
Test | Scenario | in CRC's | CRC deaths | | Gained | | Gained 3%
100% compliance:
| guideline surveillance
Hemoccult II | 40,10,05-98/$4,50 | −65,949 | −52,055 | −418,291,105 | 470,434 | 205,556,566 | 192,007 | 1,071
IFOBT 98% specificity | 70,17,09-98/$4.50 | −88,030 | −63,304 | −826,064,174 | 573,709 | 83,110,600 | 232,909 | 357
IFOBT 98% specificity | 70,17,09-98/$18 | −88,030 | −63,304 | −297,163,502 | 573,709 | 414,541,652 | 232,909 | 1,780
IFOBT 98% specificity | 70,17,09-98/$27 | −88,030 | −63,304 | 55,436,947 | 573,709 | 635,495,687 | 232,909 | 2,729
IFOBT 98% specificity | 70,17,09-98/$28 | −88,030 | −63,304 | 94,614,774 | 573,709 | 660,046,135 | 232,909 | 2,834
IFOBT 95% specificity | 70,17,09-95/$4.50 | −87,891 | −63,207 | −218,659,200 | 572,154 | 462,794,391 | 232,138 | 1,994
IFOBT 95% specificity | 70,17,09-95/$18 | −87,891 | −63,207 | 310,200,312 | 572,154 | 794,206,329 | 232,138 | 3,421
IFOBT 95% specificity | 70,17,09-95/$27 | −87,891 | −63,207 | 662,773,320 | 572,154 | 1,015,147,621 | 232,138 | 4,373
IFOBT 95% specificity | 70,17,09-95/$28 | −87,891 | −63,207 | 701,948,098 | 572,154 | 1,039,696,653 | 232,138 | 4,479
Hemoccult –SENSA | 70,17,09-92.5/$4.50 | −87,737 | −63,165 | 284,602,919 | 571,815 | 1,039,696,653 | 232,107 | 3,342
Hemoccult –SENSA | 70,17,09-92.5/$28 | −87,737 | −63,165 | 1,205,219,051 | 571,815 | 1,039,696,653 | 232,107 | 5,827
| More surveillance: (every 3 years)
Hemoccult II | 40,10,05-98/$4,50 | −76,474 | −56,747 | 46,967,784 | 498,244 | 453,692,724 | 202,108 | 2,245
IFOBT 98% specificity | 70,17,09-98/$4.50 | −101,646 | −69,221 | −141,402,524 | 608,292 | 449,039,461 | 245,381 | 1,830
IFOBT 98% specificity | 70,17,09-98/$28 | −101,646 | −69,221 | 770,673,804 | 608,292 | 1,021,113,112 | 245,381 | 4,161
IFOBT 95% specificity | 70,17,09-95/$4.50 | −101,506 | −69,110 | 463,741,807 | 606,808 | 826,542,231 | 244,693 | 3,378
IFOBT 95% specificity | 70,17,09-95/$28 | −101,506 | −69,110 | 1,375,741,577 | 606,808 | 1,398,580,548 | 244,693 | 5,716
| Other compliance levels:
Hemoccult II | 40,10,05-98/$6,75/60% compl. | −45,553 | −38,119 | −212,286,055 | 338,027 | 197,556,556 | 136,817 | 1,444
IFOBT 98% specificity | 70,17,09-98/$4.50/90% compl. | −82,781 | −60,436 | −770,072,214 | 542,142 | 89,198,446 | 219,931 | 406
IFOBT 98% specificity | 70,17,09--98/$28/90%compl. | −82,781 | −60,436 | 65,421,034 | 542,142 | 612,654,174 | 219,931 | 2,786

Incremental cost-effectiveness ratios can be easily calculated from the data provided in Table 4. For example, at a discount rate of 3%, the ICER for IFOBT with 98% specificity, and assuming equal unit cost of $4.50, is negative, that is, it is cost-saving compared to Hemoccult II, it results in more life-years gained at lower cost. This follows from the fact that we are assuming increased sensitivity at equal specificity, resulting in more life years saved and treatment costs avoided with about the same level of diagnostic and surveillance costs. At a unit cost of $28.00 for this IFOBT compared to $4.50 for Hemoccult II the ICER increases to about $11,000 per additional life-year gained as a result of using IFOBT instead of Hemoccult II. Assuming a specificity of 95% for IFOBT the ICER when compared to Hemoccult II is about $6,000 per added life-year assuming a unit cost of $4.50 and about $21,000 per added life-year assuming a unit cost of $28.00 for IFOBT. When compared to Hemoccult Sensa, IFOBT with a specificity of 98% is cost-saving even at a unit cost of $28.00. However, for IFOBT with a specificity of 95%, the ICER at $28, compared to Hemoccult Sensa at $4.50, adds very high costs for essentially the same level of life-years gained. In this last case, the modest cost advantage of somewhat better specificity is out-weighed by the cost-disadvantage of the much high unit cost of the screening test.

Clearly, if we assume a specificity of 98% for IFOBT, it is a test that would be economically preferred to Hemoccult II at the current level of payment and be preferred to Hemoccult Sensa even at a much high payment level. When we assume a payment level of $28 for IFOBT the additional benefits of the test, compared to Hemoccult II come at various levels of additional economic costs depending on the assumed level of specificity. While the ICER values in this case are multiples of the cost-effectiveness of Hemoccult II compared to no screening, they are well within the range of what is conventionally considered to be economically reasonable.

Figure 2 displays the life years gained per costs in a sensitivity analysis for IFOBT with specificities of 98% and 95% with increasing sensitivity for colorectal cancers and adenomas compared to the base case of Hemoccult II with 40% sensitivity for colorectal cancer and 98% specificity. Tests that have higher sensitivity and equal specificity ([underlined: colored] symbols to the left and above the base-case) result in more life-years gained and lower net cost (because of more savings in treatment costs avoided) while tests that have higher sensitivity but lower specificity ([underlined: open] symbols to the right and above the base-case) result in more life-years gained but substantially higher net cost because of higher costs related to diagnostic follow-up of false positive screening tests. These effects are also reflected numerically in Table 4. For example, comparing row 2 and row 4 for Table 4, it can be seen, that everything else equal, the test with 95% specificity (row 4) results in substantially greater costs and a substantially less favorable ACER that the test with 98% specificity (row 2).

Figure 2 Simulated costs and effects per mln individuals age 65–79 alive at the start of the program

Base case: HCII (40,10,05–98), to which iFOBT with +25, +50, +75% and +100% higher sensitivity and 98%/ 95% specificity is compared.

Additional sensitivity analyses are given in Table 4 for more frequent surveillance compared to current guidelines and with lower compliance for Hemoccult II versus IFOBT. Even with more extensive surveillance every 3 years for all with adenomas detected, the ACER’s range from $2728 to $6617.

## Threshold Payment Analysis

Table 5 tells us that if we make the more favorable assumption about the specificity (98%) for IFOBT, a payment level in the range of $10 to $14 but no higher, might be justifiable. But if the true specificity of IFOBT is closer to 95%, a payment greater than the current $4.50 could not be justified on comparative cost-effectiveness grounds, even though the absolute cost effectiveness ratios may fall within boundaries that are conventionally considered reasonable (Table 4). If the true specificity of IFOBT is closer to 95%, the threshold value payment level is less than $4.50 and even less than zero when sensitivity ranges from 40% to 80% and the sensitivity for colorectal cancer is four times that for adenomas of size ≥ 1.0 cm. However a threshold value of $18 is obtained for IFOBT if sensitivity for colorectal cancer increases to 87% and the sensitivity for colorectal cancer is 1.75 times that for adenomas of size ≥1.0.

Table 5 Threshold analysis: unit costs in $US for iFOBT costs resulting in equal cost-effectiveness (ACER and ICER) compared to the base case (Hemoccult II or Sensa) test for different combinations of test sensitivity and specificity. Simulations with MISCAN-colon.

base (hemoccult) | | Comparison: iFOBT
HCII: 40,10,05-98 | | 40,10,05-98 | 50,12,06-98 | 60,15,07-98 | 70,17,09-98 | 80, 20,10-98 | 87,48,24-98
Guideline surveillance
for equal ACER | | 4.50 | 7.08 | 8.99 | 11.27 | 12.44 | 29.02
for equal ICER | | 4.50 | 7.08 | 9.00 | 11.28 | 12.45 | 29.04
| | 40,10,05-95 | 50,12,06-95 | 60,15,07-95 | 70,17,09-95 | 80, 20,10-95 | 87,48,24-95
for equal ACER | | −10.55 | −8.17 | −6.30 | −4.23 | −3.22 | 12.08
for equal ICER | | −10.55 | −8.17 | −6.29 | −4.22 | −3.21 | 12.10
Sensa: 70,17,09-92.5% | | | | | 70,17,09-98 | | 87,48,24-98
Guideline surveillance
for equal ACER | | | | | 32.82 | | 56.88
for equal ICER | | | | | 32.93 | | 63.71
| | | | | 70,17,09-95 | | 87,48,24-95
for equal ACER | | | | | 17.25 | | 39.90
for equal ICER | | | | | 17.25 | | 46.68
Sensitivity analyses:
1. More surveillance (every 3 years)
HCII: 40,10,05-98 | | 40,10,05-98 | 50,12,06-98 | 60,15,07-98 | 70,17,09-98 | 80, 20,10-98
for equal ACER | | 4.50 | 6.25 | 7.55 | 8.68 | 8.93
for equal ICER | | 4.50 | 6.47 | 7.95 | 9.19 | 9.53
2. Higher (50%) compliance for iFOBT
40,10,05-98/60% compliance/6.75$ | | | | | 70,17,09-98/90%compl.
for equal ACER | | | | | 14.75
for equal ICER | | | | | 15.03
Base: iFOBT 70,17,09 | | Comparison: Hemoccult II and Hemoccult Sensa
Guideline surveillance
(all results for equal ACER) | | HCII: 40,10,05-98/new surveil.
IFOBT 70,17,09-98/$27 | | 16.98
IFOBT 70,17,09-98/$18 | | 9.84
| | Sensa: 70,17,09-92.5%/new surveil.
IFOBT 70,17,09-98/$27 | | −130
IFOBT 70,17,09-98/$18 | | −10.27
IFOBT 70,17,09-95/$27 | | 14.25
IFOBT 70,17,09-95/$18 | | 5.25

It could be argued that IFOBT should be compared to Hemoccult-SENSA as the base case rather than Hemoccult-II because Hemoccult-SENSA is available and increasingly used in the United States at the current Medicare reimbursement level of $4.50. While the higher sensitivity of SENSA is a desirable characteristic, this advantage is somewhat blunted in the context of a program of annual screening, and there is a cost disadvantage associated with the lower specificity in the range of 90–94%. Assuming specificity of 92.5% for Hemoccult SENSA would have a cost effectiveness about double that of Hemoccult II. If we assume the lower bound of 94% for the Hemoccult SENSA, the tests are essentially equivalent and the threshold payment level of IFBOT would not be much greater than the $4.50 for Hemoccult II SENSA Still, in absolute terms this is within the range of cost effectiveness at $4270 per life years gained which is far under $50,000 per life years gained that is often cited as a reasonable benchmark for reasonable value for money. So it could be argued that is reasonable for those with a preference for higher sensitivity to use Hemoccult-SENSA. Most studies suggest that Hemoccult SENSA and IFOBT have roughly similar sensitivity values so the point of comparison between the two is the difference in specificity. If we assume the lower bound value of 95% for IFOBT and the upper bound value of 94% for Hemoccult SENSA, the two tests are essentially equivalent and the threshold payment level of IFOBT would not be much greater than $4.50. But if we assume the less favorable value of 92.5% specificity for Hemoccult SENSA, and the 95% – 98% range of specificity for IFOBT, the threshold payment level for IFOBT would be considerably higher, as shown in Table 5. At the lower value of 95% specificity for IFOBT the threshold payment level would be about $17.00 when compared to SENSA at 92.5% specificity. At the upper value of 98% specificity for IFOBT, the threshold payment level would be almost $33.00. Figure 3 shows the costs and health effects of these scenarios compared to the Hemoccult II base case. Note, assuming a lower value of specificity for Hemoccult SENSA relative to IFOBT increases the estimated threshold payment for IFOBT but also decreases the rationale for adopting Hemoccult SENSA, rather than Hemoccult II as the base case.

Figure 3 Simulated costs and effects per mln individuals age 65–79 alive at the start of the program

Base case: Sensa (70,17,09–92.5), to which iFOBT with the same sensitivity (70,17,09) and 98/95% specificity is compared.

## Sensitivity Analyses

### Best Case for IFOBT

We consider that the package insert claims for InSure to be the best-case assumptions that could be made for sensitivity and specificity for this particular IFOBT. These results are similar to those presented in May 2003 (Cole, 2003) and described above. The estimates of sensitivity are based on very small clinical series (n=240) of high-risk individuals. The estimate of specificity is based on a small sample (n=90) of individuals who had previously received negative colonoscopy examinations. The values estimated from these studies are: specificity = 98% (95% Confidence Interval: 92% – 100%), sensitivity for cancer = 87% (95% Confidence Interval: 70% – 97%), sensitivity for large adenomas = 48% (95% Confidence Interval: 25% – 71%). The reported sensitivity is based on relative sensitivity compared to Hemoccult SENSA. These results suggest that the sensitivity of IFOBT for adenomas of size ≥ 1.0 is approximately half the level as for detecting colorectal cancer. This assumption for sensitivity for adenomas of size ≥ 1.0 cm is a much higher rate of detection of the large adenomas than assumed previously (25% of the colorectal cancer rate). As shown in Table 5, when compared to the base case that we have associated with Hemoccult II, the payment level that yields equivalent cost-effectiveness for this best case scenario is about $29. When compared to Hemoccult SENSA as the base case, the threshold payment level associated with IFOBT, assuming the package insert claims, would be about $60. It is worth noting that this particular scenario uses test performance characteristics estimated in a single study for an IFOBT performed in a small and possibly atypical patient population, while the performance characteristics for the base case Hemoccult II and Hemoccult SENSA are based on a conservative reading of a broad range of studies. There are no studies that we know of that confirm this result through large studies have average risk individuals in a screening setting comparing IFOBT directly to Hemoccult. This best case scenario for IFOBT is illustrated in Figure 4.

Figure 4 Simulated costs and effects per mln individuals age 65–79 alive at the start of the program

Base case: HCII (40,10,05–98), to which the "claimed" iFOBT with sensitivity 87, 48, 24 and 98/95% specificity is compared.

### IFOBT as the Base Case

Here we consider the situation where a payment level of IFOBT has been established and we ask the question: what would be the corresponding threshold payment level of Hemoccult II and Hemoccult SENSA. We performed threshold analyses assuming payments levels of $18 and $27 for IFOBT. Results of this analysis are shown in the bottom panel of Table 5. If a specificity of 98% is assumed for IFOBT, the threshold payment levels corresponding to $18 and $27 payment levels for IFOBT are about $10 and $17 for Hemoccult II. At a specificity of 98% for IFOBT corresponding threshold payment levels of Hemoccult SENSA would be less than the current payment of $4.50. But if a specificity of 95% were assumed for IFOBT than the corresponding threshold payments levels for Hemoccult SENSA would be about $5 (corresponding to the $18 payment for IFOBT) and about $14 (corresponding to the $27 payment for IFOBT).

### Non-Guideline Surveillance (More intensive surveillance)

We have assumed that surveillance in performed in compliance with current clinical guidelines. However, there is evidence that surveillance procedures may often be performed more intensively than currently recommended (Knopf 2001, Mysliwiec 2003). Figure 5 shows the affect of more intensive surveillance. Life-years saved are increased slightly while costs are increased substantially. The relative cost-effectiveness advantage of screening tests that are more sensitive for the detection of adenomas would diminish with more intensive surveillance practices.

Figure 5 Simulated costs and effects per mln individuals age 65–79 alive at the start of the program

Sensitivity analysis: iFOBT compared with HCII with more surveillance (every 3 years)

### Less Than 100% Compliance

Because dietary restrictions are not required prior to the administration of IFOBTs, it is possible that compliance may be higher for these tests, especially compared to SENSA (Young, 2002). Also the InSure IFOBT test uses a novel brush collection method which can increase willingness to complete the test (Cole 2003. In order to explore the implications of differing test compliance, we assume (using test sensitivity and specificity values shown in Table 2) that only 60% of the population complies per year with screening in a situation with annual screening in the base case. For any individual, compliance with the current test is assumed to be independent of compliance in the past tests, i.e., we assume random compliance. We also assume that with the new test, compliance increases from 60% to 90% compliance (50% increase in compliance for IFOBT compared to Hemoccult II), again random. We assume that Medicare pays $4.50 for 100% of test kits that are given to patients, for an effective cost of $6.75 per kit in the case of 60% compliance.

The last panel (rows) of Table 4 shows the results of differing assumptions about compliance in completion of the FOBT test. The next to last panel of Table 5 shows that the threshold payment level of a high compliance IFOBT with 98% specificity would be almost $15 rather than almost $11 in the case where compliance is equal for both tests. Figure 6 illustrates these affects of compliance.

Figure 6 Simulated costs and effects per mln individuals age 65–79 alive at the start of the program

Sensitivity analysis: iFOBT compared with HCII with 50% higher compliance for iFOBT