# METHODS

## Description of MISCAN-COLON Simulation Model

The MISCAN-COLON model is a [underlined: Mi]cro-simulation [underlined: S]creening Analysis [underlined: Can]cer model designed to simulate the natural history of the adenoma-carcinoma sequence in a population with and without colorectal cancer screening. A large number of fictitious individual life histories are simulated and each life has a risk of developing one or more adenomas. The life history is first simulated by drawing a date of birth and subsequent date and cause of death (other than due to colorectal cancer) for each member of the simulated cohort. Simulated life histories are created for a population with the age distribution of the U.S. population at the beginning of the screening program. For a screening program beginning in 2000 for those ages 65–79, these life histories should include cohorts born in 1921 and later. From a simulated population of 1 million, the number of simulated individuals surviving to age 65–79 to the beginning of the screening program is about 72,000 per simulation. Individuals age into and out of this population over the course of the screening program.

This approach simulates an age-structured dynamic population which is used to assess the impact of a new intervention within a population of varying ages. The risk of developing an adenoma differs within a population and is a function of a risk index and the age-specific risk of developing an adenoma. Some adenomas will progress on to cancer and some of these will cause death due to colorectal cancer. Some people will never develop a lesion, while others may develop more than one lesion. An individual is at risk of developing an adenoma up until time of death. This simulated cohort represents persons without any participation in colorectal cancer screening. Next, a program of periodic screening for colorectal cancer is simulated for this dynamic cohort and these screening tests will change some of the life histories, depending on whether a detectable but preclinical adenoma or cancer is present in each hypothetical individual, depending on the sensitivity and specificity of the test and depending on stage of cancer that would have been clinically detected in the absense of screening and depending on whether the individual would have died of cancer sooner than other causes of death in the absence of screening. MISCAN-COLON and other simulation models use estimates of “event sensitivity” as a model assumption and input. Separate event sensitivities can be incorporated into the MISCAN model for detection of large (≥1.0 cm) and for small adenomas (< 1cm) as well as for colorectal cancer. As noted below, the availability of information on event sensitivity for cancers and for adenomas vary depending on the study design to assess sensitivity.

Input assumptions affecting adenoma prevalence, colorectal cancer incidence and mortality, are calibrated so that the observed adenoma prevalence, colorectal cancer incidence and colorectal cancer mortality (USA) are reproduced by the model. A summary of the model’s assumptions for screening and surveillance are given in Table 3. For those hypothetical individuals exposed to screening the additional costs of screening are added and for all positive test results, including false positive results, the additional costs of diagnostic and surveillance procedures are added. For those individuals in which preclinical adenomas or cancer are detected by screening, time of death is changed if, for that person, the individual would have died of colorectal cancer in the absence of screening. Medical costs are also added or subtracted depending on the change in stage of disease detected and the change in the individual’s life span after colorectal cancer diagnosis. All changes in costs and life time due to the screening program are accumulated over the entire life-span of all individuals who have been subjected to the screening program.

Table 3 Main assumptions in the expert MISCAN-COLON model, established in expert meetings at the National Cancer Institute in 1996 and 1997

Parameter | Value | Based on
Distribution birth over calendar years | | Age distribution in SEER data
Life tables of deaths from other causes than colorectal cancer | | Age-specific mortality rates in US population in 1989–1991
Adenoma incidence | Age dependent: 40–49 yrs: 0.9% per yr 50–59 yrs: 1.9% per yr 60–69 yrs: 3.3% per yr 70–79 yrs: 2.6% per yr | Adenoma prevalence in autopsy and colonoscopy studies of 15% in age group 50–59 to 33% in age group 70+, cancer incidence in SEER registry in 1978 (before screening started NCI, SEER 2001)
Distribution of risk for adenomas over the general population | Gamma distributed, mean 1, variance 2 | Multiplicity distribution of adenomas in autopsy studies (Koreas 1993)
Duration distributions in preclinical stages | Exponential | Expert opinion, other cancer models (Walter 1983; Gyrd-Hansen 1997; Launoy 1997)
Mean duration of non-progressive adenomas | Lifelong | Expert opinion
mean duration of progressive adenomas | 16.4 yrs on average, exponentially distributed | Expert opinion
Site distribution, transition from each preclinical invasive stage | Calibrated to: | site distribution of clinical cancers in SEER data in 1978 (before screening started)
mean duration of preclinical cancer | 3.6 yrs on average, exponential distributed | Cancer detection rate at first screening and background cancer incidence in FOBT trials (Hardcastle 1989; Kronborg 1989)
Correlation between durations | 100% between durations in preclinical stages
Probability to develop cancer from removed adenoma | 0% | Expert opinion
Sensitivity of FOBT tests for carcinomas and for adenomas of various size, and specificities of FOBT tests | Varied | See this report
Sensitivity of diagnostic and surveillance colonoscopy for adenomas | ≤5mm: 80% 6–9mm: 85% 10+mm: 95% | Back-to-back colonoscopy studies (Hixson 1991; Rex, Cutler, Lemmel, et al 1997; Rex, Rahmani, Haseman, et al)
Sensitivity of diagnostic and surveillance colonoscopy for cancer | 95% | Back-to-back colonoscopy studies
Dependency between tests | No dependency
Site dependency | No site dependency
Diagnostic follow-up after positive result for each test and each preclinical stage | Yes
Prognosis after screening | After screen detection of a polyp: 100% cure After screen detection of a cancer: new survival based on stage-specific survival of clinical cancer
Surveillance: follow-up interval after detection of adenomas at screening or surveillance (surveillance test: colonoscopy) | 1 or 2 <1cm adenomas: after 5 years; 3+ adenomas or 1+ adenoma ≥1cm: after 3 years; after negative surveillance: 5 years; sensitivity analysis: surveillance every 5 year life-long | New AGA recommendations (Winawer, 2003)
Attendance to screening | 100%; sensitivity analysis: HCII 60% (costs of the FOBT kit is accounted for 100%) and IFOBT 90%

Details of the parameter estimation and validation for the MISCAN-COLON model are given in several published articles (Loeve 1999; 2000; 2001) that are attached as Appendix 1. In addition during the initial development of the MISCAN-colon model a validation study was performed comparing MISCAN-colon simulations against the results of the Minnesota Colon Cancer Control (MCCC) trial (Mandel 1993 and 1999; Loeve 1998). As much as possible the simulation was specified to replicate the conditions of MCCC trial, which was complicated by several factors, including switching from unredydrated to rehydrated FOBT, by an initial 2 year recruitment phase in the trial and by two phase of screening in the trial, from 1975 to 1982 and 1986 to 1992. In 1993 the MCCC reported an observed statistically significant mortality reduction from annual FOBT of 32%. With additional follow-up MCCC reported a mortality reduction of 33% for annual FOBT and 21% for biennial FOBT. The MISCAN-colon simulation of the trial predicted a mortality reduction of 34.6% for annual FOBT and 20% for biennial FOBT.

In these papers and reports validating the MISCAN model we made the assumption that the sensitivity of Hemoccult II for cancer was 60% which is higher than that assumed for this report (40% for Hemoccult II for colorectal cancer). In assuming a lower sensitivity for cancer we have not recalibrated the estimate of preclinical cancer duration to assure global consistencey with observed age specific cancer incidence as was done in the original model. However, we believe that this will not have an important efect relative to the outcomes modeled here.

The simulation model is used to derive the number of colorectal cancer cases and deaths, life years and the costs with and without screening options.

## Assumptions of the model and simulations

For the purposes of this report, the following assumptions were made:

[underlined: Screening Program:]

- The economic evaluations were conducted in the context of a program of annual FOBT screening for Medicare recipients.
- It was assumed that the program of screening was initiated in 2000 and was in effect for the duration of 30 years.
- All persons between the ages of 65 and 79 were assumed to receive annual FOBT screening during the duration of the screening program.
- The health effects and costs associated with the screening program, however, were followed for the entire life of each person.
- No person had received any type of colorectal screening procedure prior to age 65.
- All individuals were 100% compliant with screening and follow-up diagnostic and surveillance procedures.
- Individuals with an adenoma detected will continue to have surveillance colonoscopies until a diagnosis of colorectal cancer or death from other causes. The timing of the surveillance interval will depend on the number, size, and histology findings of the initial findings (Winawer, 2003)

While the assumed screening program is clearly unrealistic, this “what-if” scenario has utility for making relative cost effectiveness comparisons between different tests. We use sensitivity analysis with variation in the range of these parameters and assessed how much these changes in parameter estimates changed the outcomes from the model.

[underlined: Costs:] The allowed payment level of guaiac FOBT was set at $4.50 and included the 20% co-payment from the patient. The allowed payment level of IFOBT was varied across a range of values in the threshold payment analysis. Cost of diagnostic follow-up, surveillance and treatment procedures based on actual Medicare payment levels, were assumed to be as follows. The estimated costs for colonoscopy and polypectomy are based on information provided by CMS on Medicare payment rates for 2002 for colonoscopy procedures (CPT 45378 and CPT 45380) and polypectomy procedures (CPT 45383, 45385, 45385) performed in free standing clinic settings, on outpatient hospital settings and in ambulatory surgical settings. The weighted average payment across these settings was $646 for diagnostic colonoscopy and $683 for diagnostic colonoscopy plus biopsy. Average payment levels for polypectomy ranged from $691 to $760 depending on the specific CPT code. Based on this information we assumed an average payment level of $650 for diagnostic colonoscopy and $750 for polypectomy.

Estimates of costs for initial, continuing and terminal treatment for colorectal cancer were based on Medicare payment data from the SEER-Medicare database (Brown 1999). Cost estimates for colorectal cancer cases diagnosed between 1990 and 1994 were updated to 2002 using price adjusters from CMS, the PPS index for Part A payments, the MEI index for Part B payments, and an added 15% to take out of pocket costs into account. Based on this information we assume that the average payment level is $26,800 for the initial treatment of colorectal cancer, $2,100 annually for continuing care cost following initial cancer treatment, and $21,700 for terminal care costs for those who die of colorectal cancer.

Discounting: In the main analyses both heath effects and costs are discounted at 3% per year.

## Cost-effectiveness measures

For purposes of this report the cost-effectiveness of FOBT is expressed as dollars per life-year gained from an ongoing program of annual screening for persons age 65–79, compared to no screening. Life-years gained result from reduced mortality from colorectal cancer due to the early detection of colorectal cancer and to the detection and removal of pre-cancerous lesions, some of which would have developed into invasive clinical cancer in the absence of their detection and removal. Costs included in the analysis include the cost of the screening test itself, the cost of any subsequent diagnostic follow-up and surveillance procedures, and the cost of cancer treatment either curative or palliative. Cost for the guaiac based tests is $4.50, the Medicare approved level for a guaiac test. For comparison purposes we first set the cost values for a new immunochemical test at $4.50 (the current value for the guaiac test) and then consider higher values as well.

Cost effectiveness ratios are described for Hemoccult II and Hemoccult SENSA at a payment level of $4.50 and IFOBT at payment levels of $4.50 and $28.00. We also describe threshold payment levels for IFOBT that result in cost-effectiveness ratios equal to those for Hemoccult II and Hemoccult SENSA at payment levels of $4.50 for these two tests. Finally, we describe threshold payment levels for Hemoccult II and Hemoccult SENSA that would result in cost-effectiveness ratios equal to those for IFOBT at payment for IFOBT of $18 and $27.

In the case of screening, compared to no screening, additional costs are incurred from screening and follow-up procedures, but there is also the potential for some off-setting cost-savings because the treatment cost for pre-invasive and less advanced disease is less expensive compared to more advanced disease. This analysis includes only direct medical costs paid for by the Medicare program and Medicare recipients in the form of co-payment and deductible payments. We do not include such indirect costs as the time-cost incurred by patients in undergoing screening and treatment and indirect costs attributable to family care-giving. Nor do we include the cost of medical care unrelated to colorectal cancer associated with life-years gained from screening.

We also have not incorporated quality of life considerations into the analysis because the quality of life literature in regard to all phases of colorectal cancer screening and treatment is still very preliminary and beyond the scope of this current work. Loeve (1998) did do an exploratory study on the potential effects of taking quality of life into account in the MISCAN-Colon model. Using estimates of quality of life decrements from screening similar to those documented for breast cancer screening and preliminary estimates of quality of life following diagnosis and treatment simulations were run with and without quality of life considerations. The quality of life impact was relatively small. For example for annual unrehydrated FOBT the simulated life-years gained from screening was 9% less quality-adjusted life years compared to unadjusted life-years, using a 3% discount rate. While this difference is not negligible, differences of this magnitude are unlikely to have a substantial impact on the kinds of analyses presented in this report. The results from this exploratory analysis are similar to those obtained by De Koning (1991) in assessing the impact of quality of life on cost-effectiveness for breast cancer. He used quality of life estimates for screening and treatment based on a survey of clinical experts and found that that the quality of life considerations had only a modest impact on cost-effectiveness estimates for mammography screening.

We use the simulation model to derive the costs per life year saved for different screening options. The cost-effectiveness ratios are based on a comparison of a screening intervention compared to no screening intervention. This measure is also called the average cost-effectiveness ratio (ACER). Alternatively a cost-effectiveness ratio can be derived comparing the costs and effectiveness of one screening program to the costs and effectiveness of another screening program. These relative cost effectiveness ratios are the incremental cost effective ratios (ICER). In this setting the ACER and ICER values are similar and we only report the ACER values for the cost-effectiveness ratios in the tables and give the ICER in the tables of Appendix 3.

We also use the ACER and ICER values to derive threshold values for the cost of a new immunochemical test which would provide equivalent effectiveness (life years gained) for cost expended as that for the base case guaiac tests with a reimbursement of $4.50. The threshold value for IFOBT can be derived iteratively. Alternatively a graphical solution to deriving a threshold value is illustrated in the Appendix 2.