# LIMITATIONS

Several limitations to this analysis should be noted:

## Screening Program

For our main analysis, we have assumed a screening program consisting of annual FOBT only. The benefit of increased sensitivity is likely to be greater for screening programs characterized by longer screening intervals, e.g. biennial or triennial screening or by sporadic schedules of screening. We chose to focus on annual screening because this is allowed under current Medicare coverage policy. Nevertheless, it is possible that the threshold payment level of IFOBT might be somewhat higher in the context of other screening schedules.

We have assumed that no screening takes place prior to age 65 and that there is no use of endoscopy, e.g. screening sigmoidoscopy, in combination with FOBT as allowed under current Medicare coverage policy. If screening sigmoidoscopy were assumed to be used in the screening program, the incremental cost-effectiveness of FOBT in addition to sigmoidoscopy would likely be much less favorable than in this report. For example, in the study of Lieberman et al. (2001) the addition of rehydrated FOBT to a one-time screening sigmoidoscopy examination resulted in a statistically non-significant increase in sensitivity (using colonoscopy as the gold standard) for advanced neoplasia from 70.3% to 75.8%. This would clearly result in large increases in the absolute cost-effectiveness ratios for all FOBTs and lower incremental benefits for more sensitive tests.

There is evidence that compliance to diagnostic follow-up and surveillance is much lower than 100%. (Winawer 2003) This would reduce the cost saving associated with a screening program with higher specificity but it would also reduce the effective sensitivity of any test. We also assume a protocol of diagnostic follow-up and surveillance in accordance with current U.S. clinical guidelines. There is evidence that much more intensive and costly patterns of surveillance are often used in community practice. This factor would increase the cost savings associated with screening programs of higher specificity.

## Other Considerations

IFOBT tests are less likely that the guaiac tests of Hemoccult II or Hemoccult SENSA to result in false positive tests due to the detection of blood originating from the upper gastrointestinal tract. This may result in the performance of upper gastrointestinal endoscopy examinations following some false positive FOBT tests. We have not included this consideration in our simulations. To do so we would have to add additional costs related to false positive FOBT tests. Nevertheless, it is likely that consideration of this factor could result in somewhat more favorable threshold payment levels for IFOBT. Upper gastrointestinal endoscopy is recommended for these patients (Zuckerman 2000) even though several authors have reported a low yield for this procedure when the patient has no symptoms. Thomas and Hardcastle (1990) used the data from the Nottingham fecal occult blood test randomized trial to suggest that upper gastrointestinal investigations need not be performed routinely in asymptomatic persons with positive FOBT’s but negative colonoscopies. They suggest that this procedure be reserved for those with symptoms. Retrospective studies suggest that there is a low clinical yield for upper gastrointestinal endoscopy for such patients. (Chen 1993; Ali 2003).

These analyses have been conducted from the perspective of medical payments allowed by the Medicare program. Significantly, this excludes the time cost that accrues to both patients to undergo the screening and diagnostic procedures and the uncompensated physician time that might be associated with advising the patient to participate in screening. If these costs were counted the absolute cost effectiveness estimates would increase by substantial margins and this would affect the rationale for considering Hemoccult SENSA as an alternative base case.

When adjusting the duration of pre-clinical cancer to observed colorectal cancer detection rate in the trials 60% sensitivity was assumed. However in these analyses we have made the assumption of 40% sensitivity for colorectal cancer for Hemoccult II. For this report we have not recalibrated the model. This would suggest that in this report there could be an underestimate of the screening effect. But this does not clearly affect the comparison between higher and lower sensitivity in this report.

If recalibrated we would have a longer duration for preclinical cancer but this is neutralized by the lower sensitivity. The shorter duration of preclinical cancer the more higher sensitivity helps. We didn’t underestimate the extra benefits of higher sensitivity. We had a shorter duration now than if we recalibrated, so if anything we have underestimated rather than over estimated the benefits of increased sensitivity.

Finally, it is clear that a large element of uncertainty is associated with this analysis because of the paucity of reliable data on the test characteristics of IFOBT and Hemoccult-SENSA. The first large screening trial to report a mortality benefit from FOBT screening relied primarily on rehydrated Hemoccult. But rehydrated Hemoccult is no longer recommended for use. Several large European screening trials used un-rehydrated FOBT. There are few, if any, studies of Hemoccult-SENSA and the IFOBTs that fulfill the features of an optimal study design for determining the true performance characteristics of these tests relative to un-rehydrated FOBT: a large prospective study involving previously unscreened, a symptomatic individuals with contemporaneous confirmation by a gold standard procedure where alternatives tests are administered to the same individual or randomly assigned to subsets of individuals from the same study population. Of recent studies the one that comes closest to fulfilling these conditions is the Veterans Administration study reported by Lieberman et al. (2001). In this study, the study population was asymptomatic and unscreened. This population was of higher than average risk but numerous correlates of risk were also collected. Colonoscopy was used as a gold standard. Several screening modalities were tested contemporaneously, but only one FOBT test was considered and, due to the prominence of the Minnesota FOBT trial when the VA study was initiated, this was rehydrated FOBT. Such studies are expensive and logistically complex but additional studies of this type comparing the newer FOBTs may be worth considering as long as several alternative types of FOBT tests remain under consideration as primary modalities for colorectal cancer screening.